# Appendix G: Field Reviewers

- Stephanie Abbott, M.A.
- Adjunct Professor
- Marymount University
- Arlington, Virginia

- Raymond P. Adams, M.P.S., CAP
- Drug Court Substance Abuse Counselor
- Florida 16th Judicial Circuit Court
- Marathon, Florida

- David Bergman, J.D.
- Director of Legal and Government Affairs
- American Association for Marriage and Family Therapy
- Alexandria, Virginia

- James Bertone, LCSW, LADC
- Rehabilitation Specialist II
- Bureau of Alcohol and Drug Abuse
- Carson City, Nevada

- Thomas W. Blume, Ph.D., LPC, LMFT, NCC
- Associate Professor
- Doctoral Program Coordinator
- Oakland University
- Rochester, Michigan

- Lane Brigham, Ph.D.
- Thibodaux, Louisiana

- Susanne Caviness, Ph.D. (CAPT, USPHS)
- Senior Program Management Officer Substance Abuse and Mental Health Services Administration
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Paula Corey
- Senior Vice President
- Palladia, Inc.
- New York, New York

- Janice M. Dyehouse, Ph.D., R.N., M.S.N. Professor of Nursing
- University of Cincinnati
- College of Nursing
- Cincinnati, Ohio

- Jo‐an M. Fox
- Nashville, Tennessee

- Joel Frank
- Milwaukee, Wisconsin

- Anne M. Herron, M.S.
- Director
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, New York

- M. Kay Keller, M.P.A., SSW
- Senior Human Services Program Specialist
- Contract Manager Program
- Department of Children and Family Services
- Substance Abuse Program Office
- Tallahassee, Florida

- Malcolm V. King
- Substance Abuse Program Manager
- Virginia Department of Juvenile Justice
- Richmond, Virginia

- G. Richard Kinsella
- Vice President
- Syracuse Behavioral Healthcare
- Syracuse, New York

- Michael Warren Kirby, Jr., Ph.D., M.A., CAC III
- Chief Executive Officer
- Arapahoe House, Inc.
- Thornton, Colorado

- Janet M. Lerner, D.S.W., RCSW
- Administrator
- Narco Freedom, Inc.
- New York, New York

- Ruby J. Martinez, Ph.D., R.N., CS
- Assistant Professor
- University of Colorado
- Denver, Colorado

- Dan A. McRight
- Nashville CPE Partnership
- Nashville, Tennessee

- Jerry Moe, M.A.
- National Director
- Betty Ford Center’s Children’s Program
- Rancho Mirage, California

- Fariha Niazi, LMHC
- Brief Therapy Institute
- NOVA Southeastern University
- Fort Lauderdale, Florida

- William (Bill) Francis Northey, Jr., Ph.D.
- Research Specialist
- American Association for Marriage and Family Therapy
- Alexandria, Virginia

- Gwen M. Olitsky, M.S.
- Founder and C.E.O.
- The Self‐Help Institute for Training and Therapy
- Lansdale, Pennsylvania

- Randall W. Phillips, LMFT, LPC/MHSP
- Union City Medical Center
- Counseling and Consulting Services
- Union City, Tennessee

- Gerard J. Schmidt, M.A., LPC, MAC
- Clinical Affairs Consultant
- National Association of Alcoholism and Drug Abuse Counselors
- The Association for Addiction Professionals
- Morgantown, West Virginia

- Thomas L. Sexton, Ph.D.
- Professor and Director
- Center for Adolescent and Family Studies
- Counseling Psychology Program
- Indiana University‐Bloomington
- Bloomington, Indiana

- Meri Shadley, Ph.D., MFT, LADC
- Associate Professor
- Center for the Application of Substance Abuse Technologies
- University of Nevada, Reno
- Reno, Nevada

- Mary K. Shilton
- Executive Director
- National Treatment Accountability for Safer Communities
- Washington, DC

- Robert Walker, M.S.W., LCSW
- Assistant Professor
- University of Kentucky
- Center on Drug and Alcohol Research
- Lexington, Kentucky

- Sis Wenger
- Executive Director
- National Association for Children of Alcoholics
- Rockville, Maryland

- Kerry W. Wicks, LAC
- Program Director
- ND Department of Human Services
- Jamestown, North Dakota

- Ann S. Yabusaki, Ph.D.
- Substance Abuse Director
- Psychologist
- Coalition for a Drug‐Free Hawaii
- Substance Abuse Programs and Training
- Kaneohe, Hawaii