# Appendix F: Cultural Competency and Diversity Network Participants

- Elmore T. Briggs, CCDC, NCAC II President/CEO
- SuMoe Partners
- Germantown, Maryland
- African American Work Group

- Frank Canizales, M.S.W.
- Management Analyst, Alcohol Program
- Indian Health Service
- Rockville, Maryland
- Native American Work Group

- Ting‐Fun May Lai, M.S.W., CSW, CASAC
- Director
- Chinatown Alcoholism Center
- Hamilton‐Madison House
- New York, New York
- Asian Work Group

- Hector Sanchez, M.S.W.
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Hispanic/Latino Work Group

- Ann S. Yabusaki, Ph.D.
- Kaneohe, Hawaii
- Asian Work Group