# Appendix E: Resource Panel

- Shirley Beckett, NCAC II
- Certification Administrator
- National Association of Alcohol and Drug Abuse Counselors
- Alexandria, Virginia

- Susanne Caviness, Ph.D. (CAPT, USPHS) Senior Program Management Officer
- Substance Abuse and Mental Health Services Administration
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Frank Canizales, M.S.W.
- Management Analyst, Alcohol Program
- Indian Health Service
- Rockville, Maryland

- Peggy Clark, M.S.W., M.P.A.
- Centers for Medicare and Medicaid Services
- Center for Medicaid and State Operations
- Baltimore, Maryland

- Christina Currier
- Public Health Analyst
- Substance Abuse and Mental Health Services Administration
- Center for Substance Abuse Treatment
- Rockville, MD

- James Gil Hill
- Director
- Office of Evaluation, Scientific Analysis and Synthesis
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Hendree E. Jones, Ph.D.
- Assistant Professor
- CAP Research Director
- Johns Hopkins University Center
- Baltimore, Maryland

- William (Bill) Francis Northey, Jr., Ph.D.
- Research Specialist
- American Association for Marriage and Family Therapy
- Alexandria, Virginia

- Hector Sanchez, M.S.W.
- Team Leader
- Substance Abuse and Mental Health Services Administration
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Karen Urbany
- Public Health Advisor
- Substance Abuse and Mental Health Services Administration
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Steve Wing
- Senior Advisor for Drug Policy
- Substance Abuse and Mental Health Services Administration
- Office of Policy and Program Coordination
- Rockville, Maryland