# Appendix D: Resources

The list of resources in this appendix is not exhaustive. The inclusion of selected resources does not necessarily signify endorsement by the Substance Abuse and Mental Health Services Administration (SAMHSA), Department of Health and Human Services.

Addiction Technology Transfer Center National Office

University of Missouri ‐ Kansas City

5100 Rockhill Road

Kansas City, MO 64110

Phone: (816) 482‐1200

Fax: (816) 482‐1101

E‐mail: no@nattc.org

Web site: www.nattc.org

The Addiction Technology Transfer Centers (ATTC) are a nationwide, multidisciplinary resource that draws upon the knowledge, experience, and latest work of recognized experts in the field of addictions. Launched in 1993 and funded by the Center for Substance Abuse Treatment (CSAT) (http://www.samhsa.gov/csat/csat.htm#_blank), part of SAMHSA, the Network today is composed of 14 independent Regional Centers (http://www.attc2.org/nointernet2/regLocations.asp) and a National Office.

Adult Children of Alcoholics (ACA)

World Services Organization, Inc.

P.O. Box 3216

Torrance, CA 90510

Phone: (310) 534‐1815

Web site: www.adultchildren.org

Adult Children of Alcoholics (ACA) is a 12‐Step, Twelve Tradition program of men and women who grew up in alcoholic or otherwise dysfunctional homes.

Adult Children Anonymous

ACA General Service Network

P.O. Box 25166

Minneapolis, MN 55458‐6166

Adult Children Anonymous is a 12‐Step program modeled after Alcoholics Anonymous. It is a spiritual program designed to help adults raised in families where either substance addiction, mental illness, or generalized dysfunction was present.

Al‐Anon

Al‐Anon Family Group Headquarters, Inc.

1600 Corporate Landing Parkway

Virginia Beach, VA 23454‐5617

Phone: 1‐888‐4AL‐ANON

Web site: www.al‐anon.org (http://www.al-anon.org)

Al‐Anon is a group of relatives and friends of alcoholics who share their experience, strength, and hope to solve their common problems. The purpose of Al‐Anon is to help families of alcoholics by practicing the Twelve Steps, by welcoming and giving comfort to families of alcoholics, and by providing understanding and encouragement to the alcoholic.

Alateen

Al‐Anon Family Group Headquarters, Inc.

1600 Corporate Landing Parkway

Virginia Beach, VA 23454‐5617

Phone: 1‐888‐4AL‐ANON

Web site: http://www.al‐anon.org/alateen.html (http://www.al-anon.org/alateen.html)

Alateen is a group made up of young Al‐Anon members, usually teenagers, whose lives have been affected by someone else’s drinking.

American Association for Marriage and Family Therapy

112 South Alfred Street

Alexandria, VA 22314

Phone: (703) 838‐9808

Fax: (703) 838‐9805

Web site: www.aamft.org

The American Association for Marriage and Family Therapy (AAMFT) is the professional association for the field of marriage and family therapy. AAMFT represents the professional interests of more than 23,000 marriage and family therapists throughout the United States, Canada, and abroad.

Association for Play Therapy (APT)

2050 North Winery Avenue

Suite 101

Fresno, CA 93703

Phone: (559) 252‐2278

E‐mail: info@a4pt.org

Web site: www.a4pt.org

The Association for Play Therapy is an organization that was formed to help children and others in need. Its mission is to advance the psychosocial development and mental health of all people through play and play therapy.

Co‐Anon Family Groups

Co‐Anon Family Groups World Services

P.O. Box 12722

Tucson, AZ 85732‐2722

Voice recorder: (520) 513‐5028 Tucson, Arizona or (800) 898‐9985 Toll Free

E‐mail: info@co‐anon.org

Web site: http://www.co‐anon.org/ (http://www.co-anon.org/)

Co‐Anon Family Groups are a fellowship of men and women who are husbands, wives, parents, relatives, or close friends of someone who is chemically dependent.

Co‐Dependents Anonymous, Inc. (CoDA)

P.O. Box 33577

Phoenix, AZ 85067‐3577

Web site: www.codependents.org

Co‐Dependents Anonymous, Inc. (CoDA) is a fellowship of men and women whose common purpose is to develop healthy relationships. CoDA relies on the Twelve Steps and Twelve Traditions for knowledge and wisdom.

Families Anonymous

P.O. Box 3475

Culver City, CA 90231‐3475

Fax: (310) 815‐9682

Web site: www.familiesanonymous.org

Families Anonymous is a nonprofit organization that provides emotional support for relatives and friends of individuals with substance or behavioral problems using the 12 Steps.

The National Association for Children of Alcoholics

11426 Rockville Pike, Suite 100

Rockville, MD 20852

Phone: (888) 55‐4COAS, or (301) 468‐0985

Fax: (301) 468‐0987

E‐mail: nacoa@nacoa.org

Web site: http://www.nacoa.org/

NACoA is the national nonprofit membership organization working on behalf of children of alcohol and drug dependent parents. NACoA’s mission is to advocate for all children and families affected by alcoholism and other drug dependencies.

Nar‐Anon Family Group

Nar‐Anon World Service Office

302 West 5th Street, #301 San Pedro, CA 90731

Phone: (310) 547‐5800

Web site: www.naranon.com

Nar‐Anon Family Group is a 12‐Step Recovery program for the families and friends of individuals addicted to drugs and alcohol.

Substance Abuse and Mental Health Services Administration (SAMHSA)

www.samhsa.gov

SAMHSA is the Federal agency charged with improving the quality and availability of prevention, treatment, and rehabilitative services in order to reduce illness, death, disability, and cost to society resulting from substance abuse and mental illnesses. SAMHSA is composed of three Centers to carry out this mission: the Center for Substance Abuse Treatment, the Center for Mental Health Services, and the Center for Substance Abuse Prevention.

U.S. Department of Health and Human Services

Families & Children

Web site: www.dhhs.gov/children/index.shtml

This Web site provides information and resources for and about families and children under several categories, including adoption, babies, children, family issues (child support, child care, domestic violence, child abuse), for low‐income families, HHS agencies, immunizations/vaccinations, kids’ Web sites, pregnancy, safety and wellness, teenagers, teen Web sites, and other resources.

WestEd

730 Harrison Street

San Francisco, CA 94107

Phone: (415) 565‐3000 or toll‐free at (877) 4‐WestEd

Web site: www.WestEd.org

WestEd is a nonprofit research, development, and service agency. The agency traces its history back to 1966 when Congress created a network of Regional Educational Laboratories. WestEd is committed to improving learning at all stages of life—from infancy to adulthood, both in school and out. The agency’s work is far‐reaching because its purpose is ambitious: success for every learner.