# Appendix C: Guidelines for Assessing Violence

It is up to therapists to assess the potential for anger and violence and construct therapy so it can be conducted without endangering any family members. Because of the life‐and‐death nature of this responsibility, the consensus panel included recommended guidelines for the screening and treatment of people caught up in the cycle of domestic violence. These recommendations are adapted from TIP 25, Substance Abuse Treatment and Domestic Violence (Center for Substance Abuse Treatment 1997b ).

If, during the screening interview, it becomes clear that a batterer is endangering a client, the treatment provider should respond to this situation before any other issue, and if necessary, suspend the rest of the screening interview until the safety of the client can be ensured. The provider should refer the client to a domestic violence program and possibly to a shelter and legal services.

## Screening guidelines for domestic violence and other abusive behavior

1. To determine if someone has endured domestic violence, look for physical injuries, especially patterns of untreated injuries to the face, neck, throat, and breasts. Other indicators may include
  - Inconsistent explanations for injuries and evasive answers when questioned about them
  - Complications in pregnancy, including miscarriage, premature birth, and infant illness or birth defects
  - Stress‐related illnesses and conditions such as headache, backache, chronic pain, gastrointestinal distress, sleep disorders, eating disorders, and fatigue
  - Anxiety‐related conditions, such as heart palpitations, hyperventilation, and panic attacks
  - A sad, flat affect or talk of suicide
  - History of relapse or noncompliance with substance abuse treatment plans
2. Always interview clients about domestic violence in private. Ask about violence using concrete examples and hypothetical situations rather than vague, conceptual questions. Screening questions should convey to survivors that no battering is justified and that substance abuse is not an acceptable excuse for violent behavior.
3. As soon as it is clear that a client has been or is being battered, domestic violence experts should be contacted.
4. The provider should contact a forensics expert to document the physical evidence of battering.
5. Referrals should be made whenever appropriate for psychotherapy and specialized counseling. Staff training in domestic violence is important so that substance abuse treatment counselors can respond effectively to a domestic violence crisis.
6. A survivor of domestic violence who relocates to another community should be referred to the appropriate shelter programs within that community.
7. Because batterers in treatment frequently harass their partners (threatening them by phone, mail, and messages sent through approved visitors), telephone and visitation privileges of batterers and survivors in residential substance abuse treatment programs should be carefully monitored.
8. The discussion of family relationships, which is an element of all substance abuse screening interviews, can be used to identify domestic violence and gauge its severity.
9. A good initial question to investigate the possibility that a client is abusing family members is, “Do you think violence against a partner is justified in some situations?” A third‐person example may be used, followed by specific, concrete questions that define the extent of the violence:
  - What happens when you lose your temper?
  - When you hit (person), was it a slap or a punch?
  - Do you take car keys away? Damage property? Threaten to injure or kill (person)?
10. Once it has been confirmed that a client has been abusive—whether physically, sexually, or psychologically—the provider should contact a domestic violence expert, either for referral or consultation. Treatment providers should ensure that the danger the batterer poses is carefully assessed.
11. The provider should be direct and candid, avoiding vague or euphemistic language, such as, “Is your relationship with your partner troubled?” Instead, ask about “violence,” and keep the focus on behavior.
12. Become familiar with batterers’ rationalization and excuses for their behavior:
  - Minimizing: “I only pushed her.” “She bruises easily.” “She exaggerates.”
  - Claiming good intentions: “When she gets hysterical, I have to slap her to calm her down.”
  - Blaming intoxication: “I was drunk.” “I’m not myself when I drink.”
  - Pleading loss of control: “Something snapped.” “I can only take so much.” “I was so angry, I didn’t know what I was doing.”
  - Faulting the partner: “She drove me to it.” “She really knows how to get to me.”
  - Shifting blame to someone or something else: “I was raised that way.” “My probation officer is putting a lot of pressure on me.” “I’ve been out of work.” Substance abuse treatment providers should frame screening questions so that they do not allow a batterer to blame the person battered or a drug.
13. When treating a client who batters, providers should try to ensure the safety of those who have been or may be battered (partners and children, usually) during any crisis that precedes or occurs during the course of his treatment.
14. Treatment providers should mandate that batterers sign a “no‐violence contract” stating that the client will refrain from using violence in‐ and outside the program.
15. Treatment providers should determine the relationship between the substance abuse and the violent behavior:
  - When you take/drink (substance), exactly when does the violence occur?
  - How much of your violent behavior occurs while you are drinking or on other drugs?
  - What substances lead to violence?
  - What feelings do you have before and during the use of alcohol or other drugs?
  - Do you use substances to get over the violent incident?
16. After identifying the chain of events that precedes or triggers violent episodes, the provider and client should formulate strategies for modifying those behaviors and recognizing emotions that contribute to violent behavior.
17. Providers of services to clients who batter should watch for signs that the clients are misinterpreting the 12‐Step philosophy to excuse continued violence. For example, the first step is admitting powerlessness over alcohol. Thus the client may be one short rationalization away from excusing a violent act while intoxicated, which is later justified because the substance “made me do it.” Another danger is that batterers will call their partners “codependent” to shift blame for battering to the person harmed.
18. Referrals to self‐help aftercare groups such as Batterers Anonymous should be made only after the client has completed a batterers’ intervention program and has remained nonviolent for a specified period of time.

## Screening for child abuse

1. Inquiries into possible child abuse should not occur until the limits of confidentiality, as defined in Title 42, Part II, of the Code of Federal Regulations (or 42 C.F.R­, II) have been explained and the client has acknowledged receipt of this information in writing. Clients also must be informed that mandated reporters (such as substance abuse treatment providers) are required to notify a child protective services agency if they suspect child abuse or neglect.
2. During initial screening, the interviewer should attempt to determine whether a client’s children have been physically or emotionally harmed and whether their behavior has changed. Have they become mute? Do they scream, cry, or act out?
3. The substance abuse treatment provider should not assess children for abuse or incest. Only personnel with special expertise should perform this delicate function. The treatment provider should, however, note any indications of child abuse occurring in a client’s household and pass these suspicions on to the appropriate agency.
4. Indications of child abuse that can crop up in a client interview include:
  - Has a protective services agency been involved with anyone who lives in the home?
  - Do the children’s behaviors, such as bedwetting or sexual acting out, indicate abuse?
  - Is extraordinary closeness noted between a child and another adult in the household?
  - Does the client report blackouts? (Batterers often claim to black out during a violent episode.)
5. If a treatment provider suspects that a client’s child has been violently abused, the provider must immediately refer the child to a health care provider. If the parent will not take the child to a doctor (who is required by law to report suspected abuse), the provider must contact home health services or child protective services.
6. If the treatment provider reports suspected or definite child abuse or neglect, the provider must assess the impact on any client also being battered and develop a safety plan if one is deemed necessary.
7. Providers should be aware that if a child has been or is being abused by the mother’s partner, it is likely that the mother is also being abused.