# Appendix B: Glossary

Affect Feeling or emotion, especially as manifested by facial expression or body language.

Affective/spiritual acculturation A family’s sense of connectedness to its ethnic traditions.

BCT Behavioral couples therapy.

Behavioral acculturation The degree to which a family participates in traditional or dominant‐culture activities as opposed to other culture‐specific activities.

BMT Behavioral marital therapy.

Boundary An invisible though often effective barrier within a relationship that governs the level of contact. Boundaries can appropriately shape and regulate relationships. Two dysfunctional types of boundaries are those that are so rigid, inhibiting meaningful interaction so that the people in the relationship are said to be “disengaged” from each other, or so loose that individuals lose a sense of independence so that the “enmeshed” relationship stifles individuality and initiative.

CBT Cognitive–behavioral therapy.

Codependence A state of being overly concerned with the problems of another, to the detriment of one’s own wants and needs.

Cognitive acculturation A client’s grasp of and the extent of his involvement in the customs, beliefs, values, and language of a given culture.

Complementarity A pattern of human interactions in which partners in an intimate relationship establish roles and take on behavioral patterns that fulfill the unconscious needs and demands of the other.

Disengagement The state of being unreachably aloof or distant from others.

Ecological view of substance abuse A conception of substance abuse that is analogous to that of an ecological system in nature. Substance abuse occurs within a complex of systems, including families, communities, and societies. It may be assumed that all of the elements of this “ecological” system will have some influence on all the other elements.

Enmeshment The state of being in which two people are so close emotionally that one perceives the other as “smothering” him or her with affection, concern, attention, etc. Enmeshment also can occur without a conscious sense of it.

Family structure Repeated, predictable patterns of interaction between family members that influence individual behavior to a considerable extent.

Family therapy An approach to therapy based on the idea that a family is—and behaves as—a system. Interventions are based on the presumption that when one part of the system changes, other parts will change in response. Family therapists therefore look for unhealthy structures and faulty patterns of communication.

Family‐involved therapy The programmatic involvement of family members in the substance abuse treatment program to correct family relationships that provoke or support continued substance abuse. Family‐involved therapy is distinct from family therapy in that it may not view the entire family as the object of therapeutic interest and may not always intervene in the family’s relational system.

Genogram A pictorial chart of the people involved in a three‐generational relationship system, marking marriages, divorces, births, geographical location, deaths, and illness. Significant physical, social, and psychological dysfunction may be added. A genogram assists the therapist in understanding the family and is used to examine a family’s relationships.

Homeostasis. A natural process in which multigenerational competing forces seek to maintain a state of equilibrium i.e., balance.

Idiopathic Of, relating to, or designating a disease having no known cause.

Integrated models A constellation of interventions that takes into account each family member’s issues as they relate to the substance abuse and the effect of each member’s issues on the family system.

IP Identified patient.

MFT Marriage and family therapy.

One‐person family therapy Therapy incorporating a family focus without treating the whole family.

Phases of family change A model of family change that includes three elements occurring in a series: attainment of sobriety, adjustment to sobriety, and long‐term maintenance of sobriety.

Psychoeducation A combination of information about substance abuse and recovery, group support, and examination of interactions that result in conflict. Facilitators collaborate with the family to change these provocative interactions, reduce household stress, and create an atmosphere conducive to recovery.

Social/environmental acculturation A family’s patterns of socialization or acquisition of familiarity with its social and environmental elements.

Somatic Of, relating to, or affecting the body.

Stages of change One model of the phases of substance abuse recovery: precontemplation, contemplation, preparation, action, and maintenance.

Traditional family. The nuclear family two parents and minor children all living under the same roof, single parent, and families including blood relatives, foster relationships, grandparents raising grandchildren, and stepfamilies.

Triangulation This occurs when two family members dealing with a problem come to a place where they need to discuss a sensitive issue. Instead of facing the issue, they divert their energy to a third member who acts as a go‐between, scapegoat, object of concern, or ally. By involving this other person, they reduce their emotional tension, but prevent their conflict from being resolved and miss opportunities to increase the intimacy in their relationship.