# Appendix A: Bibliography

Alcoholics Anonymous World Services. Alcoholics Anonymous: The Story of How Many Thousands of Men and Women Have Recovered from Alcoholism. 3d ed. New York: Alcoholics Anonymous World Services, 1976.
Alexander D.E., Gwyther R.E. (1995). Alcoholism in adolescents and their families: Family‐focused assessment and management. Pediatric Clinics of North America.
Alexander, J., and Parsons, B.V. Functional Family Therapy. Monterey, CA: Brooks/Cole Pub. Co., 1982.
Alexander, J., Waldon, H.B., Newberry, A.M., and Liddle, N. The Functional Family Therapy model. In: Friedman, A.S., and Granick, S., eds. Family Therapy for Adolescent Drug Abuse. Lexington, MA: Lexington Books/D.C. Heath and Company, 1990. pp. 183–199.
Alexander J.F., Robbins M.S., Sexton T.L. (2000). Family‐based interventions with older, at risk youth: From promise to proof to practice. The Journal of Primary Prevention.
Amaro H., Hardy‐Fanta C. (1995). Gender relations in addiction and recovery. Journal of Psychoactive Drugs.
American Academy of Pediatrics. Inhalant abuse. Pediatrics 97(3):420–423, 1996. http://www.aap.org/policy/re9609.html [Accessed February 11, 2004].
American Academy of Pediatrics. (2001). Alcohol use and abuse: A pediatric concern. Pediatrics.
American Association for Marriage and Family Therapy. Marriage and Family Therapy Licensing and Certification: Directory of State MFT Licensing/Certification Boards. Alexandria, VA: American Association for Marriage and Family Therapy, 2001. http://www.aamft.org/resources/Online_Directories/boardcontacts.htm [Accessed February 11, 2004].
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th Text Revision ed. Washington, DC: American Psychiatric Association, 2000.
Anderson, J.Z. Stepfamilies and substance abuse: Unique treatment considerations. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. 2d ed. Boston: Allyn and Bacon, 1992. pp. 172–189.
Aponte, H.J., and Van Dusen, J.M. Structural family therapy. In: Gurman, A.S., and Kniskern, D.P., eds. Handbook of Family Therapy: Vol. 1. New York: Brunner/Mazel, 1981. pp. 310–358.
Ariel J., McPherson D.W. (2000). Therapy with lesbian and gay parents and their children. Journal of Marital and Family Therapy.
Atkinson R.M., Tolson R.L., Turner J.A. (1990). Late versus early onset problem drinking in older men. Alcoholism: Clinical and Experimental Research.
Attneave, C. American Indians and Alaska Native families: Emigrants in their own homeland. In: McGoldrick, M., Pearce, J.K., and Giordano, J., eds. Ethnicity and Family Therapy. New York: Guilford Press, 1982. pp. 55–83.
Azrin N.H. (1976). Improvements in the community‐reinforcement approach to alcoholism. Behaviour Research and Therapy.
Azrin N.H., Donohue B., Besalel V.A., Kogan E.S., Acierno R. (1994). Youth drug abuse treatment: A controlled outcome study. Journal of Child and Adolescent Substance Abuse.
Azrin N.H., Donohue B., Teichner G.A., Crum T., Howell J., DeCato L.A. (2001). A controlled evaluation and description of individual‐cognitive problem solving and family‐behavior therapies in dually‐diagnosed, conduct‐disordered and substance‐dependent youth. Journal of Child and Adolescent Substance Abuse.
Azrin N.H., Sisson R.W., Meyers R., Godley M. (1982). Alcoholism treatment by disulfiram and community reinforcement therapy. Journal of Behavior Therapy and Experimental Psychiatry.
Bagarozzi D.A. (1982). The family therapist’s role in treating families in rural communities: A general systems approach. Journal of Marital and Family Therapy.
Barker, P. Basic Family Therapy. 4th ed. Oxford: Blackwell Science Ltd, 1998.
Barnes, J.S., and Bennett, C.E. The Asian Population: 2000. Census 2000 Brief. Washington, DC: U.S. Census Bureau, 2002. http://www.census.gov/prod/2002pubs/c2kbr01‐16.pdf [Accessed February 11, 2004].
Barrett M.S., Berman J.S. (2001). Is psychotherapy more effective when therapists disclose information about themselves?. Journal of Consulting and Clinical Psychology.
Bavolek, S.J. Alcohol, Anger and Abuse: Understanding the Relationship Between Alcohol and Other Drug Abuse, and Child Abuse and Neglect. Park City, UT: Family Development Resources, 1995.
Bays J. (1990). Substance abuse and child abuse: Impact of addiction on the child. Pediatric Clinics of North America.
Beauvais F. (1992). The consequences of drug and alcohol use for Indian youth. American Indian and Alaska Native Mental Health Research.
Beck, A.T. Cognitive Therapy and the Emotional Disorders. New York: International Universities Press, 1976.
Beels C.C. (2002). Notes for a cultural history of family therapy. Family Process.
Bengtson V.L. (2001). Beyond the nuclear family: The increasing importance of multigenerational bonds. Journal of Marriage and the Family.
Bepko C., Johnson T. (2000). Gay and lesbian couples in therapy: Perspectives for the contemporary family therapist. Journal of Marital and Family Therapy.
Bepko, C., and Krestan, J.A. The Responsibility Trap: A Blueprint for Treating the Alcoholic Family. New York: Free Press, 1985.
Berenson D. (1976). Family approach to alcoholism. Psychiatric Opinion.
Berenson, D., and Schrier, E.W. Current family treatment approaches. In: Graham, A.W., Schultz, T.K., and Wilford, B.B., eds. Principles of Addiction Medicine. 2d ed. Chevy Chase, MD: American Society of Addiction Medicine, 1998. pp. 1115–1125.
Berg, I.K. Solution‐focused brief therapy with substance abusers: In: Washton, A.M., ed. Psychotherapy and Substance Abuse: A Practitioner’s Handbook. New York: Guilford Press, 1995. pp. 223–242.
Berg, I.K., and Miller, S.D. Working with the Problem Drinker: A Solution‐Focused Approach. New York: W.W. Norton, 1992.
Berg, I.K., and Reuss, N. Solutions Step‐By‐Step: A Substance Abuse Treatment Manual. New York: W.W. Norton, 1997.
Bernstein A.C. (2000). Straight therapists working with lesbians and gays in family therapy. Journal of Marital and Family Therapy.
Bhattacharya G. (1998). Drug use among Asian‐Indian adolescents: Identifying protective/risk factors. Adolescence.
Bianchi S.M., Casper L.M. (2000). American families. Population Bulletin.
Bijur P.E., Kurzon M., Overpeck M.D., Scheidt P.C. (1992). Parental alcohol use, problem drinking, and children’s injuries. Journal of the American Medical Association.
Blum K., Braverman E.R., Holder J.M., Lubar J.F., Monastra V.J., Miller D., Lubar J.O., Chen T.J., Comings D.E. (2000). Reward deficiency syndrome: A biogenetic model for the diagnosis and treatment of impulsive, addictive, and compulsive behaviors. Journal of Psychoactive Drugs.
Bowen M. (1974). Alcoholism as viewed through family systems theory and family psychotherapy. Annals of the New York Academy of Sciences.
Bowen, M. Family Therapy in Clinical Practice. New York: Jason Aronson, 1978.
Boyd M.R., Mackey M.C. (2000). Alienation from self and others: The psychosocial problem of rural alcoholic women. Archives of Psychiatric Nursing.
Boyd‐Franklin, N. Black Families in Therapy: A Multisystems Approach. New York: Guilford Press, 1989.
Brady K.T., Randall C.L. (1999). Gender differences in substance use disorders. Psychiatric Clinics of North America.
Brandl B., Horan D.L. (2002). Domestic violence in later life: An overview for health care providers. Women & Health.
Bratton, S., Ray, D., Rhine, T., and Jones, L. A Meta‐Analysis of the Play Therapy Outcome Research from 1947 to the Present: A Brief Summary. Fresno, CA: Association for Play Therapy, n.d. http://www.a4pt.org/Meta‐Analysis_Summary.doc [Accessed February 11, 2004].
Brook, D.W., and Brook, J.S. Family processes associated with alcohol and drug use and abuse. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. 2d ed. Boston: Allyn and Bacon, 1992. pp. 15–33.
Brooks, C., and Rice, K.F. Families in Recovery: Coming Full Circle. Baltimore: Paul H. Brookes Publishing, 1997.
Brown, S. and Lewis, V. The Alcoholic Family in Recovery: A Developmental Model. New York: Guilford Press, 1999.
Brown T.G., Kokin M., Seraganian P., Shields N. (1995). The role of spouses of substance abusers in treatment: Gender differences. Journal of Psychoactive Drugs.
Brucker P.S., Perry B.J. (1998). American Indians: Presenting concerns and considerations for family therapists. American Journal of Family Therapy.
Bry B.H. (1983). Substance abuse in women: Etiology and prevention. Issues in Mental Health Nursing.
Bucholz, K.K., Sheline, Y., and Helzer, J.E. The epidemiology of alcohol use, problems, and dependence in elders: A review. In: Beresford, T.P., and Gomberg, E., eds. Alcohol and Aging. New York: Oxford University Press, 1995. pp. 19–41.
Bukstein O.G. (2000). Disruptive behavior disorders and substance use disorders in adolescents. Journal of Psychoactive Drugs.
Bushy, A. Mental health and substance abuse: Challenges in providing services to rural clients. In: Center for Substance Abuse Treatment, ed. Bringing Excellence to Substance Abuse Services in Rural and Frontier America. Technical Assistance Publication Series 20. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997. pp. 45–53.
Caetano R., Clark C.L., Tam T. (1998). Alcohol consumption among racial/ethnic minorities: Theory and research. Alcohol Health and Research World.
Casado‐Flores J., Bano‐Rodrigo A., Romero E. (1990). Social and medical problems in children of heroin‐addicted parents: A study of 75 patients. American Journal of Diseases of Children.
Catalano R.F., Gainey R.R., Fleming C.B., Haggerty K.P., Johnson N.O. (1999). An experimental intervention with families of substance abusers: One‐year follow‐up of the Focus on Families Project. Addiction.
Celano M.P., Kaslow N.J. (2000). Culturally competent family interventions: Review and case illustrations. American Journal of Family Therapy.
Center for Substance Abuse Treatment. Improving Treatment for Drug‐Exposed Infants. Treatment Improvement Protocol (TIP) Series 5. DHHS Publication No. (SMA) 95‐3057. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1993a.
Center for Substance Abuse Treatment. Pregnant, Substance‐Using Women. Treatment Improvement Protocol (TIP) Series 2. DHHS Publication No. (SMA) 93‐1998. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1993b.
Center for Substance Abuse Treatment. Screening for Infectious Diseases Among Substance Abusers. Treatment Improvement Protocol (TIP) Series 6. DHHS Publication No. (SMA) 95‐3060. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1993c.
Center for Substance Abuse Treatment. State Methadone Treatment Guidelines. Treatment Improvement Protocol (TIP) Series 1. DHHS Publication No. (SMA) 93‐1991. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1993d.
Center for Substance Abuse Treatment. Assessment and Treatment of Cocaine‐Abusing Methadone‐Maintained Patients. Treatment Improvement Protocol (TIP) Series 10. DHHS Publication No. (SMA) 94‐3003. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994a.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients with Coexisting Mental Illness and Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series 9. DHHS Publication No. (SMA) 95‐3061. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994b.
Center for Substance Abuse Treatment. Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series 12. DHHS Publication No. (SMA) 94‐3004. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994c.
Center for Substance Abuse Treatment. Intensive Outpatient Treatment for Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series 8. DHHS Publication No. (SMA) 99‐3306. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994d.
Center for Substance Abuse Treatment. Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series 7. DHHS Publication No. (SMA) 00‐3477. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994e.
Center for Substance Abuse Treatment. Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases. Treatment Improvement Protocol (TIP) Series 11. DHHS Publication No. (SMA) 94‐2094. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1994f.
Center for Substance Abuse Treatment. Alcohol and Other Drug Screening of Hospitalized Trauma Patients. Treatment Improvement Protocol (TIP) Series 16. DHHS Publication No. (SMA) 95‐3041. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995a.
Center for Substance Abuse Treatment. Combining Alcohol and Other Drug Treatment with Diversion for Juveniles in the Justice System. Treatment Improvement Protocol (TIP) Series 21. DHHS Publication No. (SMA) 95‐3051. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995b.
Center for Substance Abuse Treatment. Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment. Treatment Improvement Protocol (TIP) Series 14. DHHS Publication No. (SMA) 95‐3031. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995c.
Center for Substance Abuse Treatment. Detoxification from Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series 19. DHHS Publication No. (SMA) 95‐3046. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995d.
Center for Substance Abuse Treatment. LAAM in the Treatment of Opiate Addiction. Treatment Improvement Protocol (TIP) Series 22. DHHS Publication No. (SMA) 95‐3052. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995e.
Center for Substance Abuse Treatment. Matching Treatment to Patient Needs in Opioid Substitution Therapy. Treatment Improvement Protocol (TIP) Series 20. DHHS Publication No. (SMA) 95‐3049. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995f.
Center for Substance Abuse Treatment. Planning for Alcohol and Other Drug Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series 17. DHHS Publication No. (SMA) 95‐3039. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995g.
Center for Substance Abuse Treatment. The Role and Current Status of Patient Placement Criteria in the Treatment of Substance Use Disorders. Treatment Improvement Protocol (TIP) Series 13. DHHS Publication No. (SMA) 95‐3021. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995h.
Center for Substance Abuse Treatment. The Tuberculosis Epidemic: Legal and Ethical Issues for Alcohol and Other Drug Abuse Treatment Providers. Treatment Improvement Protocol (TIP) Series 18. DHHS Publication No. (SMA) 95‐3047. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995i.
Center for Substance Abuse Treatment. Checklist for Monitoring Alcohol and Other Drug Confidentiality Compliance. Technical Assistance Publication Series 18. DHHS Publication No. (SMA) 99‐3321. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996a.
Center for Substance Abuse Treatment. Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing. Treatment Improvement Protocol (TIP) Series 23. DHHS Publication No. (SMA) 96‐3113. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996b.
Center for Substance Abuse Treatment. A Guide to Substance Abuse Services for Primary Care Clinicians. Treatment Improvement Protocol (TIP) Series 24. DHHS Publication No. (SMA) 97‐3139. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997a.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Domestic Violence. Treatment Improvement Protocol (TIP) Series 25. DHHS Publication No. (SMA) 97‐3163. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1997b.
Center for Substance Abuse Treatment. Comprehensive Case Management for Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 27. DHHS Publication No. (SMA) 98‐3222. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998a.
Center for Substance Abuse Treatment. Continuity of Offender Treatment for Substance Use Disorders From Institution to Community. Treatment Improvement Protocol (TIP) Series 30. DHHS Publication No. (SMA) 98‐3245. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998b.
Center for Substance Abuse Treatment. Naltrexone and Alcoholism Treatment. Treatment Improvement Protocol (TIP) Series 28. DHHS Publication No. (SMA) 98‐3206. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998c.
Center for Substance Abuse Treatment. Substance Abuse Among Older Adults. Treatment Improvement Protocol (TIP) Series 26. DHHS Publication No. (SMA) 98‐3179. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998d.
Center for Substance Abuse Treatment. Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series 29. DHHS Publication No. (SMA) 98‐3249. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998e.
Center for Substance Abuse Treatment. Brief Interventions and Brief Therapies for Substance Abuse. Treatment Improvement Protocol (TIP) Series 34. DHHS Publication No. (SMA) 99‐3353. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999a.
Center for Substance Abuse Treatment. Enhancing Motivation for Change in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series 35. DHHS Publication No. (SMA) 99‐3354. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999b.
Center for Substance Abuse Treatment. Screening and Assessing Adolescents for Substance Use Disorders. Treatment Improvement Protocol (TIP) Series 31. DHHS Publication No. (SMA) 99‐3282. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999c.
Center for Substance Abuse Treatment. Treatment for Stimulant Use Disorders. Treatment Improvement Protocol (TIP) Series 33. DHHS Publication No. (SMA) 99‐3296. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999d.
Center for Substance Abuse Treatment. Treatment of Adolescents With Substance Use Disorders. Treatment Improvement Protocol (TIP) Series 32. DHHS Publication No. (SMA) 99‐3283. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1999e.
Center for Substance Abuse Treatment. Integrating Substance Abuse Treatment and Vocational Services. Treatment Improvement Protocol (TIP) Series 38. DHHS Publication No. (SMA) 00‐3470. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000a.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues. Treatment Improvement Protocol (TIP) Series 36. DHHS Publication No. (SMA) 00‐3357. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000b.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37. DHHS Publication No. (SMA) 00‐3459. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2000c.
Center for Substance Abuse Treatment. A Provider's Introduction to Substance Abuse Treatment for Lesbian, Gay, Bisexual, and Transgender Individuals. DHHS Publication No. (SMA) 01‐3498. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001.
Center for Substance Abuse Treatment. Detoxification and Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development a.
Center for Substance Abuse Treatment. Improving Cultural Competence in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development b.
Center for Substance Abuse Treatment. Intensive Outpatient Treatment for Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development c.
Center for Substance Abuse Treatment. Medication‐Assisted Treatment for Opioid Addiction. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development d.
Center for Substance Abuse Treatment. Substance Abuse Treatment: Addressing the Specific Needs of Women. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development e.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Family Therapy. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development f
Center for Substance Abuse Treatment. Substance Abuse Treatment and Group Therapy. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development g.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Men’s Issues. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development h.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Trauma. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development i.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Adults in the Criminal Justice System. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development j.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons with Co‐Occurring Disorders. Treatment Improvement Protocol (TIP) Series. Rockville, MD: Substance Abuse and Mental Health Services Administration, in development k.
Centers for Disease Control and Prevention. HIV/AIDS Surveillance Report. 13(1):1–41. Atlanta, GA: Centers for Disease Control and Prevention, 2002. http://www.cdc.gov/hiv/stats/hasr1301.pdf [Accessed February 11, 2004].
Cermak, T.L. Evaluating and Treating Adult Children of Alcoholics: Volume 2, Treatment (Professional Series). Minneapolis: The Johnson Institute, 1991.
Cervantes, R.C., and Pena, C. Evaluating Hispanic/Latino programs: Ensuring cultural competence. In: Delgado, M., ed. Alcohol Use/Abuse Among Latinos: Issues and Examples of Culturally Competent Services. Binghamton, NY: Haworth Press, 1998. pp. 109–131.
Chaney, R.A., and White, W.L. Metaphors of Transformation: Feminine and Masculine. Bloomington, IL: Chestnut Health Systems, 1992.
Chang, P. Treating Asian/Pacific American addicts and their families. In: Krestan, J.‐A., ed. Bridges to Recovery: Addiction, Family Therapy, and Multicultural Treatment. New York: Free Press, 2000. pp. 192–218.
Chien, C.P., and Yamamoto, J. Asian American and Pacific Islander patients. In: Acosta, F.X., Yamamoto, J., and Evans, L.A., eds. Effective Psychotherapy for Low‐Income and Minority Patients. New York: Plenum Press, 1982. pp. 117–145.
Choney, S.K., Berryhill‐Paapke, E., and Robbins, R.R. The acculturation of American Indians: Developing frameworks for research and practice. In: Ponterotto, J.G., Casas, J.M., Suzuki, L.A., and Alexander, C.M., eds. Handbook of Multicultural Counseling. Thousand Oaks, CA: Sage Publications, 1995. pp. 73–92.
Clay R.A. (2003). SAMHSA launches buprenorphine education initiative. SAMHSA News.
Cloninger, C.R. Genetics of substance abuse. In: Galanter, M., and Kleber, H.D., eds. Textbook of Substance Abuse Treatment. 2d ed. Washington, DC: American Psychiatric Press, 1999. pp. 59–66.
Coco E.L., Courtney L.J. (1998). A family systems approach for preventing adolescent runaway behavior. Adolescence.
Co‐Dependents Anonymous. Patterns and Characteristics of Codependence. Phoenix, AZ: Co‐Dependents Anonymous, 1998. http://www.codependents.org/codapatt.html [Accessed February 11, 2004].
Cohen P., Cohen J., Kasen S., Velez C.N., Hartmark C., Johnson J., Rojas M., Brook J., Streuning E.L. (1993). An epidemiological study of disorders in late childhood and adolescence: I. Age‐ and gender‐specific prevalence. Journal of Child Psychology and Psychiatry.
Collins, R.L. Family treatment of alcohol abuse: Behavioral and systems perspectives. In: Collins, R.L., Leonard, K.E., and Searles, J.S., eds. Alcohol and the Family: Research and Clinical Perspectives. New York: Guilford Press, 1990. pp. 285–308.
Conner K.R., Shea R.R., McDermott M.P., Grolling R., Tocco R.V., Baciewicz G. (1998). The role of multifamily therapy in promoting retention in treatment of alcohol and cocaine dependence. American Journal on Addictions.
Cook, P.S., Petersen, R.C., and Moore, D.T. Alcohol, Tobacco and Other Drugs May Harm the Unborn. DHHS Publication No. (ADM) 90‐1711. Rockville, MD: Office of Substance Abuse Prevention, 1990.
Cooklin A. (2001). Eliciting children’s thinking in families and family therapy. Family Process.
Covington, S.S. Helping women recover: Creating gender‐responsive treatment. In: Straussner, S.L.A., and Brown, S., eds. Handbook of Women’s Addiction Treatment: Theory and Practice. San Francisco: Jossey Bass, 2002. pp. 52–72.
Coyhis, D. Culturally specific addiction recovery for Native Americans. In: Krestan, J., ed. Bridges To Recovery: Addiction, Family Therapy, and Multicultural Treatment. New York: The Free Press, 2000. pp. 77–114.
Cuadrado M., Lieberman L. (1998). Traditionalism in the prevention of substance misuse among Puerto Ricans. Substance Use and Misuse.
Cunningham P.B., Henggeler S.W. (1999). Engaging multiproblem families in treatment: Lessons learned throughout the development of multisystemic therapy. Family Process.
Cutler D.L., Madore E. (1980). Community‐family network therapy in a rural setting. Community Mental Health Journal.
De Jong, P., and Berg, I.K. Interviewing for Solutions. Stamford, CT: Brooks/Cole, 1997.
De Leon, G. Therapeutic communities. In: Galanter, M., and Kleber, H.D., eds. Textbook of Substance Abuse Treatment. 2d ed. Washington, DC: American Psychiatric Press, 1999. pp. 447–462.
DeLoach, C., and Greer, B.G. Adjustment to Severe Physical Disability: A Metamorphosis. New York: McGraw Hill, 1981.
de Shazer, S. Clues: Investigating Solutions in Brief Therapy. New York: W.W. Norton, 1988.
de Shazer, S. Putting Difference to Work. New York: W.W. Norton, 1991.
de Shazer S. (1997). Some thoughts on language use in therapy. Contemporary Family Therapy.
Diamond G., Liddle H.A. (1996). Resolving a therapeutic impasse between parents and adolescents in multidimensional family therapy. Journal of Consulting and Clinical Psychology.
Diamond G.S., Serrano A.C., Dickey M., Sonis W.A. (1996). Current status of family‐based outcome and process research. American Academy of Child and Adolescent Psychiatry Journal.
Diaz‐Guerrero, R. Psychology of the Mexican: Culture and Personality. Austin, TX: University of Texas Press, 1975.
Doherty W.J., Baird M.A. (1986). Developmental levels in family‐centered medical care. Family Medicine.
Douyon R., Guzman P., Romain G., reland S.J., Mendoza L., Lopez‐Blanco M., Milanes F. (1998). Subtle neurological deficits and psychopathological findings in substance‐abusing homeless and non‐homeless veterans. Journal of Neuropsychiatry & Clinical Neurosciences.
Drake R.E., McHugo G.J., Clark R.E., Teague G.B., Xie H., Miles K., Ackerson T.H. (1998). Assertive community treatment for patients with co‐occurring severe mental illness and substance use disorder: A clinical trial. American Journal of Orthopsychiatry.
Dufour M., Fuller R.K. (1995). Alcohol in the elderly. Annual Reviews of Medicine.
Duran, E., and Duran, B. Native American Postcolonial Psychology. Albany, NY: State University of New York Press, 1995.
Edwards M.E., Steinglass P. (1995). Family therapy treatment outcomes for alcoholism. Journal of Marital and Family Therapy.
Edwards, R.W. Drug and alcohol use among youth in rural communities. In: Robertson, E.B., Sloboda, Z., Boyd, G.M., Beatty, L., and Kozel, N.J., eds. Rural Substance Abuse: State of Knowledge and Issues. NIDA Research Monograph 168. NIH Publication No. 97‐4177. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 53–78.
Effective Medical Treatment of Opiate Addiction. NIH Consensus Statement 1997 Nov 17‐19. 1997. http://consensus.nih.gov/cons/108/108_statement.pdf [Accessed February 11, 2004].
Epstein, E.E., and McCrady, B.S. Couple therapy in the treatment of alcohol problems. In: Gurman, A.S., and Jacobson, N.A., eds. Clinical Handbook of Couple Therapy. 3d ed. New York: Guilford Press, 2002.
Falicov, C.J. Mexican families. In: McGoldrick, M., Giordano, J., and Pearce, J.K., eds. Ethnicity and Family Therapy. 2d ed. New York: Guilford Press, 1996. pp. 169–182.
Falicov, C.J. Latino Families in Therapy: A Guide to Multicultural Practice. New York: Guilford Press, 1998.
Falloon, I.R.H. Behavioral family therapy. In: Gurman, A.S., and Kniskern, D.P., eds. Handbook of Family Therapy: Vol. 2. New York: Brunner/Mazel, 1991. pp. 65–95.
Fals‐Stewart W., O’Farrell T.J., Birchler G.R. (1997). Behavioral couples therapy for male substance‐abusing patients: A cost outcomes analysis. Journal of Consulting and Clinical Psychology.
Famularo R., Kinscherff R., Fenton T. (1992). Psychiatric diagnoses of abusive mothers: A preliminary report. Journal of Nervous and Mental Disease.
Famularo R., Stone K., Barnum R., Wharton R. (1986). Alcoholism and severe child maltreatment. American Journal of Orthopsychiatry.
Fang S.R., Wark L. (1998). Developing cross‐cultural competence with traditional Chinese Americans in family therapy: Background information and the initial therapeutic contact. Contemporary Family Therapy: An International Journal.
Favazza A.R., Thompson J.J. (1984). Social networks of alcoholics: Some early findings. Alcoholism: Clinical and Experimental Research.
Fields, J., and Casper, L.M. America’s Families and Living Arrangements: March 2000. Current Population Reports, P20‐537. Washington, DC: U.S. Census Bureau, 2001.
Finkelstein N. (1994). Treatment issues for alcohol‐ and drug‐dependent pregnant and parenting women. Health & Social Work.
Finkelstein, N. Using the relational model as a context for treating pregnant and parenting chemically dependent women. In: Underhill, B.L., and Finnegan, D.G., eds. Chemical Dependency: Women at Risk. New York: Harrington Park Press/Haworth Press, 1996. pp. 23–44.
Fisher L., Weihs K.L. (2000). Can addressing family relationships improve outcomes in chronic disease? Report of the National Working Group on Family‐Based Interventions in Chronic Disease. Journal of Family Practice.
Fishman, H.C. Intensive Structural Therapy: Treating Families in Their Social Context. New York: Basic Books, 1993.
Fishman H.C., Andes F., Knowlton R. (2001). Enhancing family therapy: The addition of a community resource specialist. Journal of Marital and Family Therapy.
Friedman A.S., Terras A., Kreisher C. (1995). Family and client characteristics as predictors of outpatient treatment outcome for adolescent drug abusers. Journal of Substance Abuse.
Friedman, E.H. Bowen theory and therapy. In: Gurman, A.S., and Kniskern, D.P., eds. Handbook of Family Therapy: Vol. 2. New York: Brunner/Mazel, 1991. pp. 134–170.
Furstenberg F. F. (2000). The sociology of adolescence and youth in the 1990s: A critical commentary. Journal of Marriage and the Family.
Galanter, M. Network Therapy for Alcohol and Drug Abuse: A New Approach in Practice. New York: Basic Books, 1993.
Garcia‐Preto, N. Latino families: An overview. In: McGoldrick, M., Giordano, J., and Pearce, J.K., eds. Ethnicity and Family Therapy. 2d ed. New York: Guilford Press, 1996. pp. 141–154.
Gay and Lesbian Medical Association. Healthy People 2010 Companion Document for Lesbian, Gay, Bisexual, and Transgender (LGBT) Health. San Francisco: Gay and Lesbian Medical Association, 2001. http://www.glma.org/policy/hp2010/PDF/HP2010CDLGBTHealth.pdf [Accessed February 11, 2004].
Gerstein, D.R. Outcome research: Drug abuse. In: Galanter, M., and Kleber, H.D., eds. Textbook of Substance Abuse Treatment. 2d ed. Washington, DC: American Psychiatric Press, 1999. pp. 135–147.
Giglio J.J., Kaufman E. (1990). The relationship between child and adult psychopathology in children of alcoholics. International Journal of the Addictions.
Gingerich W.J., Eisengart S. (2000). Solution‐focused brief therapy: A review of the outcome research. Family Process.
Glover N.M., Janikowski T.P., Benshoff J.J. (1995). The incidence of incest histories among clients receiving substance abuse treatment. Journal of Counseling and Development.
Goldberg M.E., Lex B.W., Mello N.K., Mendelson J.H., Bower T.A. (1996). Impact of maternal alcoholism on separation of children from their mothers: Findings from a sample of incarcerated women. American Journal of Orthopsychiatry.
Gomberg E.S. (1995). Older women and alcohol: Use and abuse. Recent Developments in Alcoholism.
Goyer P.F., Davis G.C., Rapoport J.L. (1979). Abuse of prescribed stimulant medication by a 13‐year‐old hyperactive boy. Journal of the American Academy of Child Psychiatry.
Green R.J. (2000). Introduction to special section: Lesbian, gay, and bisexual issues in family therapy. Journal of Marital and Family Therapy.
Grieco, E.M. The Native Hawaiian and Other Pacific Islander Population: 2000. Census 2000 Brief. Washington, DC: U.S. Census Bureau, 2001. http://www.census.gov/prod/2001pubs/c2kbr01‐14.pdf [Accessed February 11, 2004].
Guiao I.Z., Esparza D. (1997). Family interventions with “troubled” Mexican American teens: An extrapolation from a review of the literature. Issues in Mental Health Nursing.
Guthmann‐Ternus, D.S. “An Analysis of Variables That Impact Treatment Outcomes of Chemically Dependent Deaf and Hard of Hearing Individuals.” Ed.D. dissertation, University of Minnesota, Minneapolis, MN, 1995.
Harris‐Hastick, E.F. Substance abuse issues among English‐speaking Caribbean people of African ancestry. In: Straussner, S.L.A., ed. Ethnocultural Factors in Substance Abuse Treatment. New York: Guilford Press, 2001. pp. 52–74.
Heath, A.W., and Stanton, M.D. Family‐based treatment: Stages and outcomes. In: Frances, R.J., and Miller, S.I., eds. Clinical Textbook of Addictive Disorders. 2d ed. New York: Guilford Press, 1998. pp. 496–520.
Henggeler S.W., Pickrel S.G., Brondino M.J., Crouch J.L. (1996). Eliminating (almost) treatment dropout of substance abusing or dependent delinquents through home‐based multisystemic therapy. American Journal of Psychiatry.
Henggeler, S.W., Schoenwald, S.K., Borduin, C.M., Rowland, M.D., and Cunningham, P.B. Multisystemic Treatment of Antisocial Behavior in Children and Adolescents. New York: Guilford Press, 1998.
Hernandez, M. Puerto Rican families and substance abuse. In: Krestan, J.A., ed. Bridges to Recovery: Addiction, Family Therapy, and Multicultural Treatment. New York: The Free Press, 2000. pp. 253–283.
Hernandez, M., and McGoldrick, M. Migration and the family life cycle. In: Carter, B., and McGoldrick, M., eds. The Expanded Family Life Cycle: Individual, Family, and Social Perspectives. 3d ed. Boston: Allyn and Bacon, 1999. pp. 169–173.
Herrick C.A., Brown H.N. (1998). Underutilization of mental health services by Asian‐Americans residing in the United States. Issues in Mental Health Nursing.
Higgins, S.T., and Budney, A.J. Treatment of cocaine dependence through the principles of behavior analysis and behavioral pharmacology. In: Onken, L.S., Blaine, J.D., and Boren, J.J., eds. Behavioral Treatments for Drug Abuse and Dependence. NIDA Research Monograph 137. NIH Publication No. 93‐3684. Rockville, MD: National Institute on Drug Abuse, 1993. pp. 97–121.
Higgins S.T., Budney A.J., Bickel W.K., Badger G.J. (1994). Participation of significant others in outpatient behavioral treatment predicts greater cocaine abstinence. American Journal of Drug and Alcohol Abuse.
Higgins S.T., Budney A.J., Bickel W.K., Hughes J.R., Foerg F., Badger G. (1993). Achieving cocaine abstinence with a behavioral approach. American Journal of Psychiatry.
Hines, P.M., and Boyd‐Franklin, N. African American families. In: McGoldrick, M., Pearce, J.K., and Giordano, J., eds. Ethnicity and Family Therapy. 2d ed. New York: Guilford Press, 1996. pp. 66–84.
Hodge, F.S., and Fredericks, L. American Indian and Alaska Native populations in the United States: An overview. In: Huff, R.M., and Kline, M.V., eds. Promoting Health in Multicultural Populations: A Handbook for Practitioners. Thousand Oaks, CA: Sage Publications, 1999. pp. 269–289.
Hoffmann J.P. (1995). The effects of family structure and family relations on adolescent marijuana use. International Journal of the Addictions.
Hogue A., Liddle H.A., Rowe C., Turner R.M., Dakof G.A., LaPann K. (1998). Treatment adherence and differentiation in individual versus family therapy for adolescent substance abuse. Journal of Counseling Psychology.
Hser Y.I., Hoffman V., Grella C.E., Anglin M.D. (2001). A 33‐year follow‐up of narcotics addicts. Archives of General Psychiatry.
Hudak, J., Krestan, J.A., and Bepko, C. Alcohol problems and the family life cycle. In: Carter, B., and McGoldrick, M., eds. The Expanded Family Life Cycle: Individual, Family, and Social Perspectives. 3d ed. Boston: Allyn and Bacon, 1999. pp. 455–469.
Huff, R., and Kline, M. The Cultural Assessment Framework. In: Huff, R., and Kline, M. Promoting Health in Multicultural Populations: A Handbook for Practitioners. Thousand Oaks, CA: Sage Publications, 1999. pp. 481–499.
Hughes T.L., Eliason M. (2002). Substance use and abuse in lesbian, gay, bisexual and transgender populations. Journal of Primary Prevention.
Hulnick M.R., Hulnick H.R. (1989). Life’s challenges: Curse or opportunity? Counseling families of persons with disabilities. Journal of Counseling and Development.
Human J., Wasem C. (1991). Rural mental health in America. American Psychologist.
Hunt G.M., Azrin N.H. (1973). A community‐reinforcement approach to alcoholism. Behaviour Research and Therapy.
Hunt P.L. (1987). Black clients: Implications for supervision of trainees. Psychotherapy: Theory, Research, Practice, Training.
Hurcom C., Copello A., Orford J. (2000). The family and alcohol: Effects of excessive drinking and conceptualizations of spouses over recent decades. Substance Use and Misuse.
Hurt R. (1988). D., Finlayson, R.E., Morse, R.M., and Davis, L.J., Jr. Alcoholism in elderly persons: Medical aspects and prognosis of 216 inpatients. Mayo Clinic Proceedings.
Huycke, J.D. Structural Family Therapy. Racine, WI: SAFE Haven, 2000. http://www.execpc.com/~safehavn/strucfam.htm [Accessed February 11, 2004].
Imber‐Black, E. Families and Larger Systems: A Family Therapist’s Guide Through the Labyrinth. New York: Guilford Press, 1988.
Imber‐Black, E. Multiple embedded systems. In: Mirkin, M.P., ed. The Social and Political Contexts of Family Therapy. Needham Heights, MA: Allyn and Bacon, 1990. pp. 3–18.
Imber‐Black, E. A family‐larger‐system perspective. In: Gurman, A.S., and Kniskern, D.P., eds. Handbook of Family Therapy: Vol. 2. New York: Brunner/Mazel, 1991. pp. 583–605.
Inaba, D.S., Cohen, W.E., and Holstein, M.E. Uppers, Downers, All Arounders: Physical and Mental Effects of Psychoactive Drugs. 3d ed. Ashland, OR: CNS Publications, 1997.
Indian Entities Recognized and Eligible to Receive Services from the United States Bureau of Indian Affairs. 67 Fed. Reg. 43,328, July 12, 2002.
Indian Health Service. Trends in Indian Health 1998‐99. Rockville, MD: Indian Health Service, 2002. http://www.ihs.gov/PublicInfo/Publications/trends98/trends98.asp [Accessed February 11, 2004].
Inouye, J. Asian American health and disease: An overview of the issues. In: Huff, R., and Kline, M. Promoting Health in Multicultural Populations: A Handbook for Practitioners. Thousand Oaks, CA: Sage Publications, 1999. pp. 337–356.
International Certification and Reciprocity Consortium – Alcohol and Other Drug Abuse. Standards for Certified AODA Counselors. Falls Church, VA: International Certification and Reciprocity Consortium – Alcohol and Other Drug Abuse, 2002. http://www.icrcaoda.org/standards_counselor.htm [Accessed February 11, 2004].
Isaacson, E.B. Chemical addiction: Individuals and family systems. Journal of Chemical Dependency Treatment 4(1):7–27, 1991a.
Isaacson, E.B. Psychodynamics and family systems: A model for chemical addiction counseling. Journal of Chemical Dependency Treatment 4(1):41–60, 1991b.
Ivey D.C., Wieling E., Harris S.M. (2000). Save the young—the elderly have lived their lives: Ageism in marriage and family therapy. Family Process.
Jacobson N.S., Follette W.C., Revenstorf D., Baucom D.H., Hahlweg K., Margolin G. (1984). Variability in outcome and clinical significance of behavioral marital therapy: A reanalysis of outcome data. Journal of Consulting and Clinical Psychology.
Jainchill N., Hawke J., Yagelka J. (2000). Gender, psychopathology, and patterns of homelessness among clients in shelter‐based TCs. American Journal of Drug and Alcohol Abuse.
Johnson J.L., Leff M. (1999). Children of substance abusers: Overview of research findings. Pediatrics.
Johnson M.P. (1995). Patriarchal terrorism and common couple violence: Two forms of violence against women. Journal of Marriage and the Family.
Johnson, V.E. I’ll Quit Tomorrow. New York: Harper and Row, 1973.
Johnson, V.E. Intervention: How to Help Someone Who Doesn’t Want Help. A Step‐by‐Step Guide for Families and Friends of Chemically Dependent Persons. Minneapolis, MN: Johnson Institute Books, 1986.
Johnston D. (2000). A series of cases of dementia presenting with PTSD symptoms in World War II combat veterans. Journal of the American Geriatrics Society.
Johnston, L.D., O’Malley, P.M., and Bachman, J.G. Monitoring the Future: National Results on Adolescent Drug Use. Overview of Key Findings, 2001. Bethesda, MD: National Institute on Drug Abuse, 2002. http://www.monitoringthefuture.org/pubs/monographs/overview2001.pdf [Accessed February 11, 2004].
Kalant, H. Pharmacological interactions of aging and alcohol. In: Gomberg, E.S.L., Hegedus, A.M., and Zucker, R.A., eds. Alcohol Problems and Aging. NIAAA Research Monograph No. 33. Bethesda, MD: National Institute on Alcohol Abuse and Alcoholism, 1998. pp. 99–116.
Kao, R.S.‐K., and Lam, M.L. Asian American elderly. In: Lee, E., ed. Working with Asian Americans. New York: Guilford Press, 1997. pp. 208–226.
Kaufman, E. Adolescent substance abusers and family therapy. In: Friedman, A.S., and Granick, S., eds. Family Therapy For Adolescent Drug Abuse. Lexington, MA: Lexington Books, 1990a. pp. 47‐61.
Kaufman, E. Critical aspects of the psychodynamics of substance abuse and the evaluation of their application to a psychotherapeutic approach. International Journal of the Addictions 25(2A):97–114, 1990b.
Kaufman, E. Psychotherapy of Addicted Persons. New York: Guilford Press, 1994.
Kaufman, E. Family therapy: Other drugs. In: Galanter, M., and Kleber, H., eds. Textbook of Substance Abuse Treatment. 2d ed. Washington, DC: American Psychiatric Press, 1999. pp. 389–400.
Kaufman, E., and Borders, L. Ethnic family differences in adolescent substance use. In: Coombs, R.H., ed. The Family Context of Adolescent Drug Use. New York: Haworth Press, 1988. pp. 99–121.
Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. 2d ed. Boston: Allyn and Bacon, 1992.
Kaufman E., Pattison E.M. (1981). Differential methods of family therapy in the treatment of alcoholism. Journal of Studies on Alcohol.
Kaufmann, P., and Kaufman, E. From multiple family therapy to couples therapy. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. New York: Gardner Press, 1979. pp. 95–103.
Kaufmann, P., and Kaufman, E. From multiple family therapy to couples therapy. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. 2d ed. Boston: Allyn and Bacon, 1992a. pp. 85–93.
Kaufmann, P., and Kaufman, E. Multiple family therapy with drug abusers. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. 2d ed. Boston: Allyn and Bacon, 1992b. pp. 72–84.
Kearns, D., and Rosenthal, D. Substance abuse in rural America. In: Moore, R.M., III, ed. The Hidden America: Social Problems in Rural America for the Twenty‐First Century. Selinsgrove, PA: Susquehanna University Press, 2001, pp. 151–178.
Kelleher K.J., Rickert V.I., Hardin B.H., Pope S.K., Farmer F.L. (1992). Rurality and gender: Effects on early adolescent alcohol use. American Journal of Diseases of Children.
Kelley M.L., Tseng H. (1992). Cultural differences in child rearing: A comparison of immigrant Chinese and Caucasian American mothers. Journal of Cross‐Cultural Psychology.
Kim S.C. (1985). Family therapy for Asian Americans: A strategic‐structural framework. Psychotherapy.
King S.A., Engi S., Poulos S.T. (1998). Using the Internet to assist family therapy. British Journal of Guidance & Counselling.
Kirby K.C., Marlowe D.B., Festinger D.S., Garvey K.A., LaMonaca V. (1999). Community reinforcement training for family and significant others of drug abusers: A unilateral intervention to increase treatment entry of drug users. Drug and Alcohol Dependence.
Kleinman, A., and Good, B., eds. Culture and Depression: Studies in the Anthropology and Cross‐Cultural Psychiatry of Affect and Disorder. Berkeley, CA: University of California Press, 1985.
Kline A. (1996). Pathways into drug user treatment: The influence of gender and racial/ethnic identity. Substance Use and Misuse.
Krestan, J.‐A. Addiction, power, and powerlessness. In: Krestan, J.‐A., ed. Bridges to Recovery: Addiction, Family Therapy, and Multicultural Treatment. New York: Free Press, 2000. pp. 15–44.
Lambert M.J., Okiishi J.C., Finch A.E., Johnson L.D. (1998). Outcome assessment: From conceptualization to implementation. Professional Psychology: Research and Practice.
LaSala M. (2000). Lesbians, gay men, and their parents: Family therapy for coming‐out crisis. Family Process.
Lee, E. Asian American families: An overview. In: McGoldrick, M., Giordano, J., and Pearce, J.K., eds. Ethnicity and Family Therapy. 2d ed. New York: Guilford Press, 1996. pp. 227–248.
Lee R. (2000). How to talk about sex with patients who are not heterosexual. Western Journal of Medicine.
Leipman, M.R., Wolper, B., and Vazquez, J. An ecological approach for motivating women to accept treatment for drug dependency. In: Reed, B.G., Beschner, G.M., and Mondanaro, J., eds. Treatment Services for Drug Dependent Women: Vol. 2. Treatment Research Monograph Series. DHHS Publication No. (ADM) 82‐1219. Rockville, MD: National Institute on Drug Abuse, 1982. pp. 1–61.
Leslie, D.R., Perina, B.A., and Maqueda, M.C. Clinical issues with transgender individuals. In: Center for Substance Abuse Treatment, ed. A Provider’s Introduction to Substance Abuse Treatment for Lesbian, Gay, Bisexual, and Transgender Individuals. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001. pp. 91–98.
Levin, J.D. Couple and Family Therapy of Addiction. Northvale, NJ: Jason Aronson, 1998.
Li T.K. (2000). Pharmacogenetics of responses to alcohol and genes that influence alcohol drinking. Journal of Studies on Alcohol.
Liddle H.A. (1999). Theory development in a family‐based therapy for adolescent drug abuse. Journal of Clinical Child Psychology.
Liddle H.A. (2001). Adolescent substance abuse derails development. AAMFT Clinical Update.
Liddle, H.A. Multidimensional Family Therapy for Adolescent Cannabis Users. Cannabis Youth Treatment (CYT) Series, Vol. 5. DHHS Publication No. (SMA) 02‐3660. Rockville, MD: Center for Substance Abuse Treatment, 2002.
Liddle, H.A., and Dakof, G.A. Efficacy of family therapy for drug abuse: Promising but not definitive. Journal of Marital and Family Therapy 21(4):511–543, 1995a.
Liddle, H.A., and Dakof, G.A. Family‐based treatment for adolescent drug use: State of the science. In: Rahdert, E.R., and Czechowicz, D., eds. Adolescent Drug Abuse: Clinical Assessment and Therapeutic Interventions. NIDA Research Monograph 156. NIH Publication No. 95‐3908. Rockville, MD: National Institute on Drug Abuse, 1995b. pp. 218–254.
Liddle, H.A., Dakof, G.A., and Diamond, G. Adolescent substance abuse: Multidimensional family therapy in action. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. 2d ed. Boston: Allyn and Bacon, 1992. pp. 120–171.
Liddle H.A., Dakof G.A., Parker K., Diamond G.S., Barrett K., Tejeda M. (2001). Multidimensional family therapy for adolescent drug abuse: Results of a randomized clinical trial. American Journal of Drug and Alcohol Abuse.
Liddle, H.A., and Hogue, A. Multidimensional family therapy for adolescent substance abuse. In: Wagner, E.F., and Waldron, H.B., eds. Innovations in Adolescent Substance Abuse Interventions. New York: Pergamon, 2001. pp. 229–261.
Liepman M.R., Silvia L.Y., Nirenberg T.D. (1989). The use of family behavior loop mapping for substance abuse. Family Relations.
Linehan, M.M. Cognitive‐Behavioral Treatment of Borderline Personality Disorder. New York: Guilford Press, 1993.
London E.D., Bonson K.R., Ernst M., Grant S. (1999). Brain imaging studies of cocaine abuse: Implications for medication development. Critical Reviews in Neurobiology.
Lopez, F. Confidentiality of Patient Records for Alcohol and Other Drug Treatment. Technical Assistance Publication Series 13. DHHS Publication No. (SMA) 99‐3321. Rockville, MD: Center for Substance Abuse Treatment, 1994.
Madsen, W. Mexican Americans of South Texas. New York: Holt, Rinehart, and Winston, 1964.
Makimoto K. (1998). Drinking patterns and drinking problems among Asian‐Americans and Pacific Islanders. Alcohol Health and Research World.
Marín, G., and Marín, B.V. Research with Hispanic Populations. Newbury Park, CA: Sage Publications, 1991.
Marsh, D.T. A Family‐Focused Approach to Serious Mental Illness: Empirically Supported Interventions. Sarasota, FL: Professional Resource Press/Professional Resource Exchange, 2001.
Marshak, L.E., and Seligman, M. Counseling Persons with Physical Disabilities: Theoretical and Clinical Perspectives. Austin, TX: PRO‐ED, 1993.
May Lai, T.‐F. Ethnocultural background and substance abuse treatment of Chinese Americans. In: Straussner, S.L.A., ed. Ethnocultural Factors in Substance Abuse Treatment. New York: Guilford Press, 2001. pp. 345–367.
McCollum, E.E., and Trepper, T.S. Family Solutions for Substance Abuse: Clinical and Counseling Approaches. Binghamton, NY: Haworth Press, 2001.
McCrady, B.S., and Epstein, E.E. Theoretical bases of family approaches to substance abuse treatment. In: Rotgers, F., and Keller, D.S., eds. Treating Substance Abuse: Theory and Technique. New York: Guilford Press, 1996. pp. 117–142.
McGee, G., Johnson, L., and Bell, P. Black, Beautiful, and Recovering. Center City, MN: Hazelden, 1985.
McGill, D.W., and Pearce, J.K. American families with English ancestors from the colonial era: Anglo Americans. In: McGoldrick, M., Giordano, J., and Pearce, J.K., eds. Ethnicity and Family Therapy. 2d ed. New York: Guilford Press, 1996. pp. 451–466.
McGoldrick, M. Normal families: An ethnic perspective. In: Walsh, F., ed. Normal Family Processes. New York: Guilford Press, 1982. pp. 399–424.
McGoldrick, M. You Can Go Home Again: Reconnecting with Your Family. New York: W.W. Norton, 1995.
McGoldrick, M., and Gerson, R. Genograms in Family Assessment. New York: W.W. Norton, 1985.
McLellan A.T., Arndt I.O., Metzger D.S., Woody G.E., O’Brien C.P. (1993). The effects of psychosocial services in substance abuse treatment. Journal of the American Medical Association.
McVinney, D. Clinical issues with bisexuals. In: Center for Substance Abuse Treatment, ed. A Provider’s Introduction to Substance Abuse Treatment for Lesbian, Gay, Bisexual, and Transgender Individuals. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001. pp. 87–90.
Mercado M.M. (2000). The invisible family: Counseling Asian American substance abusers and their families. Family Journal.
Merikangas K.R., Dierker L.C. (1998). Psychopathology among offspring of parents with substance abuse and/or anxiety disorders: A high‐risk study. Journal of Child Psychology and Psychiatry.
Meyers, R.J., and Smith, J.E. Clinical Guide to Alcohol Treatment: The Community Reinforcement Approach. New York: Guilford Press, 1995.
Miller L., Davies M., Greenwald S. (2000). Religiosity and substance use and abuse among adolescents in the National Comorbidity Survey. Journal of the American Academy of Child and Adolescent Psychiatry.
Miller, W.R., Andrews, N.R., Wilbourne, P., and Bennett, M.E. A wealth of alternatives: Effective treatments for alcohol problems. In: Miller, W.R., and Heather, N., eds. Treating Addictive Behaviors. 2d ed. New York: Plenum Press, 1998. pp. 203–216.
Miller W.R., Benefield R.G., Tonigan J.S. (1993). Enhancing motivation for change in problem drinking: A controlled comparison of two therapist styles. Journal of Consulting and Clinical Psychology.
Minuchin, S. Families and Family Therapy. London: Tavistock, 1974.
Minuchin, S., and Fishman, H.C. Family Therapy Techniques. Cambridge, MA: Harvard University Press, 1981.
Moll, L.C., Rueda, R.S., Reza, R., Herrera, J., and Vasquez, L.P. Mental health services in East Los Angeles: An urban community case study. In: Miranda, M.R., ed. Psychotherapy with the Spanish Speaking: Issues in Research and Service Delivery. Los Angeles: University of California, Spanish Speaking Mental Health Research Center, 1976. pp. 52–65.
Moncher M.S., Holden G.W., Trimble J.E. (1990). Substance abuse among Native‐American youth. Journal of Consulting and Clinical Psychology.
Montalvo B., Gutierrez M. (1983). A perspective for the use of the cultural dimension in family therapy. Family Therapy Collections.
Moore D., Li L. (1994). Substance use among rehabilitation consumers for vocational rehabilitation services. Journal of Rehabilitation.
Moore D., Polsgrove L. (1991). Disabilities, developmental handicaps, and substance misuse: A review. International Journal of the Addictions.
Moos R.H., Brennan P.L., Moos B.S. (1991). Short‐term processes of remission and nonremission among late‐life problem drinkers. Alcoholism: Clinical and Experimental Research.
Motet‐Grigoras C.N., Schuckit M.A. (1986). Depression and substance abuse in handicapped young men. Journal of Clinical Psychiatry.
Mueser K.T., Bond G.R., Drake R.E., Resnick S.G. (1998). Models of community care for severe mental illness: A review of research on case management. Schizophrenia Bulletin.
Muetzell S. (1995). Are children of alcoholic mothers more psychologically damaged compared with children of mothers from the general population?. Early Child Development and Care.
Murphy J.M., Jellinek M., Quinn D., Smith G., Poitrast F.G., Goshko M. (1991). Substance abuse and serious child mistreatment: Prevalence, risk, and outcome in a court sample. Child Abuse and Neglect.
Myers J. (1984). K., Weissman, M.M., Tischler, G.L., Holzer, C.E., III, Leaf, P.J., Orvaschel, H., Anthony, J.C., Boyd, J.H., Burke, J.D., Jr., Kramer, M., and Stolzman, R. Six‐month prevalence of psychiatric disorders in three communities 1980 to 1982. Archives of General Psychiatry.
Napoliello A.L., Sweet E.S. (1992). Salvador Minuchin’s structural family therapy and its application to Native Americans. Family Therapy.
National Center on Addiction and Substance Abuse. No Place to Hide: Substance Abuse in Mid‐Size Cities and Rural America. New York: National Center on Addiction and Substance Abuse, 2000. http://www.casacolumbia.org/publications1456/publications_show.htm?doc_id=23734 [Accessed February 11, 2004].
National Center on Addiction and Substance Abuse. So Help Me God: Substance Abuse, Religion and Spirituality. New York: National Center on Addiction and Substance Abuse, 2001. http://www.casacolumbia.org/usr_doc/Spirituality.pdf [Accessed February 11, 2004].
National Coalition for Homeless Veterans. Background and Statistics. Washington, DC: National Coalition for Homeless Veterans, 2002. http://www.nchv.org/background.cfm [Accessed February 11, 2004].
National Coalition for the Homeless. Who is Homeless? Washington, DC: National Coalition for the Homeless, 1999. http://www.nationalhomeless.org/who.html [Accessed February 11, 2004].
National Institute on Drug Abuse. Use of Selected Drugs Among Hispanics: Mexican‐Americans, Puerto Ricans, and Cuban‐Americans. Findings from the Hispanic Health and Nutrition Examination Survey. DHHS Publication No. (ADM) 87‐1527. Rockville, MD: National Institute on Drug Abuse, 1987.
National Institute on Drug Abuse. Principles of Drug Addiction Treatment: A Research‐Based Guide. NIH Publication No. 00‐4180. Bethesda, MD: National Institutes of Health, 1999a.
National Institute on Drug Abuse. Treatment Medications. NIDA InfoFax 13560. Rockville, MD: National Institute on Drug Abuse, 1999b. http://165.112.78.61/Infofax/treatmed.html [Accessed February 11, 2004].
National Institute on Drug Abuse. Prescription Drugs: Abuse and Addiction. National Institute on Drug Abuse Research Report Series. Rockville, MD: National Institute on Drug Abuse, 2001. http://www.nida.nih.gov/PDF/RRPrescription.pdf [Accessed February 11, 2004].
National Institute on Drug Abuse. Stress and Substance Abuse: A Special Report. Rockville, MD: National Institute on Drug Abuse, 2002. http://www.nida.nih.gov/stressanddrugabuse.html [Accessed February 10, 2004]. (http://www.nida.nih.gov/stressanddrugabuse.html)
Nelipovich M., Buss E. (1989). Alcohol abuse and persons who are blind: Treatment considerations. Alcohol Health and Research World.
New York State Education Department – Office of Bilingual Education. Directory of Languages. Albany, NY: New York State Education Department, Office of Bilingual Education, 1997. http://www.emsc.nysed.gov/ciai/biling/pub/languages.html [Accessed February 11, 2004].
Nichols, M.P., and Schwartz, R.C. The Essentials of Family Therapy. Boston: Allyn and Bacon, 2001.
Noel, N.E., and McCrady, B.S. Alcohol‐focused spouse involvement with behavioral marital therapy. In: O’Farrell, T.J., ed. Treating Alcohol Problems: Marital and Family Interventions. New York: Guilford Press, 1993. pp. 210–235.
Northey W. F. (2002). Characteristics and clinical practices of marriage and family therapists: A national survey. Journal of Marital and Family Therapy.
O’Farrell, T.J. A behavioral marital therapy couples group program for alcoholics and their spouses. In: O’Farrell, T.J., ed. Treating Alcohol Problems: Marital and Family Interventions. New York: Guilford Press, 1993. pp. 170–209.
O’Farrell, T.J., Choquette, K.A., Cutter, H.S.G., Brown, E., Bayog, R., McCourt, W., Lowe, J., Chan, A., and Deneault, P. Cost‐benefit and cost‐effectiveness analyses of behavioral marital therapy with and without relapse prevention sessions for alcoholics and their spouses. Behavior Therapy 27(1):7–24, 1996a.
O’Farrell, T.J., Choquette, K.A., Cutter, H.S., Floyd, F.J., Bayog, R., Brown, E.D., Lowe, J., Chan, A., and Deneault, P. Cost‐benefit and cost‐effectiveness analyses of behavioral marital therapy as an addition to outpatient alcoholism treatment. Journal of Substance Abuse 8(2):145–166, 1996b.
O’Farrell, T.J., and Fals‐Stewart, W. Treatment models and methods: Family models. In: McCrady, B.S., and Epstein, E.E., eds. Addictions: A Comprehensive Guidebook. New York: Oxford University Press, 1999. pp. 287–305.
O’Farrell T.J., Fals‐Stewart W. (2000). Behavioral couples therapy for alcoholism and drug abuse. Journal of Substance Abuse Treatment.
Office of Applied Studies. Prevalence of Substance Use Among Racial and Ethnic Subgroups in the United States: 1991‐1993. Analytic Series: A‐6. DHHS Publication No. (SMA) 98‐3202. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1998.
Office of Applied Studies. Summary of Findings from the 2000 National Household Survey on Drug Abuse. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001a. http://www.samhsa.gov/oas/NHSDA/2kNHSDA.pdf [Accessed February 11, 2004].
Office of Applied Studies. Treatment Episode Data Set (TEDS): 1994–1999. National Admissions to Substance Abuse Treatment Services. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2001b. http://www.samhsa.gov/oas/teds/99TEDS/99Teds.pdf [Accessed February 11, 2004].
Office of Applied Studies. National Survey of Substance Abuse Treatment Services (N‐SSATS): 2000. Data on Substance Abuse Treatment Facilities. DASIS Series: S‐16. DHHS Publication No. (SMA) 02‐3668. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2002a. http://wwwdasis.samhsa.gov/00nssats/nssats2000report.pdf [Accessed February 11, 2004].
Office of Applied Studies. Prescription and Over‐the‐Counter Drug Abuse Admissions. The DASIS Report. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2002b. http://www.samhsa.gov/oas/2k2/OTCtx/OTCtx.pdf [Accessed February 11, 2004].
Office of Applied Studies. Results from the 2001 National Household Survey on Drug Abuse: Vol.1. Summary of National Findings. National Household Survey on Drug Abuse Series: H‐17. DHHS Publication No. (SMA) 02‐3758. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2002c.
Office of Applied Studies. Results from the 2001 National Household Survey on Drug Abuse: Vol. 2. Technical Appendices and Selected Data Tables. National Household Survey on Drug Abuse Series: H‐18. DHHS Publication No. (SMA) 02‐3759. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2002d.
Office of Applied Studies. Overview of Findings from the 2002 National Survey on Drug Use and Health. (Office of Applied Studies, NHSDA Series H‐21, DHHS Publication No. SMA 03‐3774). Rockville, MD: Substance Abuse and Mental Health Services Administration, 2003a. http://www.samhsa.gov/oas/NHSDA/2k2NSDUH/2k2SoFOverviewW.pdf [Accessed February 11, 2004]. (http://www.samhsa.gov/oas/NHSDA/2k2NSDUH/2k2SoFOverviewW.pdf)
Office of Applied Studies. Veterans in Substance Abuse Treatment: 1995‐2000. The DASIS Report. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2003b. http://www.samhsa.gov/oas/2k3/VetsTX/VetsTX.pdf [Accessed March 8, 2004]. (http://www.samhsa.gov/oas/2k3/VetsTX/VetsTX.pdf)
Ogunwole, S.U. The American Indian and Alaska Native Population: 2000. Census 2000 Brief. Washington, DC: U.S. Census Bureau, 2002. http://www.census.gov/prod/2002pubs/c2kbr01‐15.pdf [Accessed February 11, 2004].
Olsen L. (1995). Services for substance abuse‐affected families: The Project Connect experience. Child and Adolescent Social Work Journal.
Onken, L.S., Blaine, J., and Boren, J.D., eds. Beyond the Therapeutic Alliance: Keeping the Drug‐Dependent Individual in Treatment. NIDA Research Monograph 165. NIH Publication No. 97‐4142. Rockville, MD: National Institute on Drug Abuse, 1997.
Osborn C.J. (1997). Does disease matter? Incorporating solution‐focused brief therapy in alcoholism treatment. Journal of Alcohol and Drug Education.
Oxford M.L., Harachi T.W., Catalano R.F., Abbott R.D. (2001). Preadolescent predictors of substance initiation: A test of both the direct and mediated effect of family social control factors on deviant peer associations and substance initiation. American Journal of Drug and Alcohol Abuse.
Paniagua, F.A. Assessing and Treating Culturally Diverse Clients: A Practical Guide. 2d ed. Thousand Oaks, CA: Sage Publications, 1998.
Pardini D.A., Plante T.G., Sherman A., Stump J.E. (2000). Religious faith and spirituality in substance abuse recovery: Determining the mental health benefits. Journal of Substance Abuse Treatment.
Penn N.E., Kar S., Kramer J., Skinner J., Zambrana R.E. (1995). Ethnic minorities, health care systems, and behavior. Health Psychology.
Pequegnat W., Bauman L.J., Bray J.H., DiClemente R., DiIorio C., Hoppe S.K., Jemmott L.S., Krauss B., Miles M., Paikoff R., Rapkin B., Rotheram‐Borus M.J., Szapocznik J. (2001). Measurement of the role of families in prevention and adaptation to HIV/AIDS. AIDS and Behavior.
Perez M., Pilsecker C. (1989). Family therapy with spinal cord injured substance abusers. Social Work in Health Care.
Pfeffer C.R., Normandin L., Kakuma T. (1998). Suicidal children grow up: Relations between family psychopathology and adolescents’ lifetime suicidal behavior. Journal of Nervous and Mental Disease.
Pinsof W.M., Wynne L.C., Hambright A.B. (1996). The outcomes of couple and family therapy: Findings, conclusions, and recommendations. Psychotherapy: Theory, Research, Practice, Training.
Pion, G.M., Keller, P., and McCombs, H. Mental Health Providers in Rural and Isolated Areas: Final Report of the Ad Hoc Rural Mental Health Provider Work Group. DHHS Publication No. (SMA) 98‐3166. Rockville, MD: Center for Mental Health Services, 1997. http://www.mentalhealth.org/publications/allpubs/SMA98‐3166/default.asp [Accessed February 11, 2004].
Polk G.W. (1996). Treatment of problem drinking behavior using solution‐focused brief therapy: A single subject design. Crisis Intervention and Time‐Limited Treatment.
Popenoe D. (1995). The American family crisis. National Forum.
Prochaska J.O., DiClemente C.C., Norcross J.C. (1992). In search of how people change: Applications to addictive behaviors. American Psychologist.
Ray W.A., Thapa P.B., Shorr R.I. (1993). Medications and the older driver. Clinics in Geriatric Medicine.
Rehabilitation Research and Training Center on Drugs and Disability. Substance Abuse, Disability and Vocational Rehabilitation. Dayton, OH: Rehabilitation Research and Training Center on Drugs and Disability, Wright State University, 1996.
Reid, D.J. Addiction, African Americans, and a Christian recovery. In: Krestan, J.A., ed. Bridges to Recovery: Addiction, Family Therapy, and Multicultural Treatment. New York: The Free Press, 2000. pp. 145–172.
Reilly, D.M. Drug‐abusing families: Intrafamilial dynamics and brief triphasic treatment. In: Kaufman, E., and Kaufmann, P., eds. Family Therapy of Drug and Alcohol Abuse. 2d ed. Boston: Allyn and Bacon, 1992. pp. 105–119.
Rhoades, J.A., and Chu, M.C. Health Insurance Status of the Civilian Noninstitutionalized Population: 1999. Rockville, MD: Agency for Healthcare Research and Quality, 2000. http://www.meps.ahrq.gov/papers/rf14_01‐0011/rf14.pdf [Accessed February 11, 2004].
Richardson D. (1991). Structural and strategic family therapy techniques: Application to chemically dependent families. Journal of Chemical Dependency Treatment.
Robbins, M.S., Schwartz, S.J., and Szapocznik, J. Structural ecosystems therapy with adolescents exhibiting disruptive behavior disorders. In: Ancis, J.R., ed. Culturally‐Based Interventions: Alternative Approaches to Working with Diverse Populations and Culture‐Bound Syndromes. New York: Brunner/Routledge, in press.
Robbins, M.S. and Szapocznik, J. Brief Strategic Family Therapy. Juvenile Justice Bulletin. Washington, DC: Office of Juvenile Justice and Delinquency Prevention, 2000. http://www.ncjrs.org/html/ojjdp/jjbul2000_04_3/contents.html [Accessed February 11, 2004].
Robert Wood Johnson Foundation. The Robert Wood Johnson Foundation Annual Report 1994: Cost Containment. Princeton, NJ: Robert Wood Johnson Foundation, 1994.
Roberts J. (1997). How to recognise a therapeutic community. Prison Service Journal.
Rose L.R. (1995). Healing from racism. Winds of Change.
Rowe D., Grills C. (1993). African‐centered drug treatment: An alternative conceptual paradigm for drug counseling with African‐American clients. Journal of Psychoactive Drugs.
Ryglewicz H. (1991). Psychoeducation for clients and families: A way in, out, and through in working with people with dual disorders. Psychosocial Rehabilitation Journal.
Sacks S., Sacks J., De Leon G., Bernhardt A.I., Staines G.L. (1997). Modified therapeutic community for mentally ill chemical “abusers”: Background; influences; program description; preliminary findings. Substance Use & Misuse.
Sandhu D.S. (1997). Psychocultural profiles of Asian and Pacific Islander Americans: Implications for counseling and psychotherapy. Journal of Multicultural Counseling and Development.
Santisteban D.A., Coatsworth J.D., Perez‐Vidal A., Mitrani V., Jean‐Gilles M., Szapocznik J. (1997). Brief structural/strategic family therapy with African American and Hispanic high‐risk youth. Journal of Community Psychology.
Santisteban D.A., Muir J.A., Mena M.P., Mitrani V.B. (2003). Integrated Borderline Adolescent Family Therapy: Meeting the challenges of treating borderline adolescents. Psychotherapy: Theory/Research/ Practice/Training.
Santisteban, D.A., Muir‐Malcolm, J.A., Mitrani, V.B., and Szapocznik, J. Integrating the study of ethnic culture and family psychology intervention science. In: Liddle, H.A., Santisteban, D.A., Levant, R.F., and Bray, J.H., eds. Family Psychology: Science‐Based Interventions. Washington, DC: American Psychological Association, 2002. pp. 331–351.
Santisteban D.A., Szapocznik J., Perez‐Vidal A., Murray E.J., Kurtines W.M., LaPerriere A. (1996). Efficacy of intervention for engaging youth and families into treatment and some variables that may contribute to differential effectiveness. Journal of Family Psychology.
Sargent A. (1983). J., III. The family: A pediatric assessment. Journal of Pediatrics.
Sayger T.V., Heid K.O. (1990). Counseling the impoverished rural client: Issues for family therapists. Psychotherapy Patient.
Schaschl S., Straw D. (1989). Results of a model intervention program for physically impaired persons. Alcohol Health and Research World.
Schmidt S.E., Liddle H.A., Dakof G.A. (1996). Changes in parenting practices and adolescent drug abuse during multidimensional family therapy. Journal of Family Psychology.
Schuckit, M.A. Drug and Alcohol Abuse: A Clinical Guide to Diagnosis and Treatment. 5th ed. New York: Kluwer Academic/Plenum Publishers, 2000.
Schwab A.J., DiNitto D.M. (1993). Factors related to the successful vocational rehabilitation of substance abusers. Journal of Applied Rehabilitation Counseling.
Sexton, T.L., and Alexander, J.F. Functional Family Therapy. Washington, DC: Office of Juvenile Justice and Delinquency Prevention, 2000. http://www.ncjrs.org/html/ojjdp/jjbul2000_12_4/contents.html [Accessed February 11, 2004].
Sexton, T.L., and Alexander, J.F. Functional family therapy for adolescents and their families. In: Patterson, T., ed. Comprehensive Handbook of Psychotherapy. New York: Wiley & Sons, 2002.
Shapiro, C. Integrating Family‐Focused Interventions into the Criminal Justice System. New York: The Vera Institute of Justice, 1999. http://www.vera.org/publications/bodegafamily.htm [Accessed February 11, 2004].
Sheahan S.L., Coons S.J., Robbins C.A., Martin S.S., Hendricks J., Latimer M. (1995). Psychoactive medication, alcohol use, and falls among older adults. Journal of Behavioral Medicine.
Sheahan S.L., Hendricks J., Coons S.J. (1989). Drug misuse among the elderly: A covert problem. Health Values.
Sheils R., Rolfe T.J. (2000). Towards an integrated approach to a family intervention for co‐occurring substance abuse and schizophrenia. Australian & New Zealand Journal of Family Therapy.
Sher K.J. (1997). Psychological characteristics of children of alcoholics. Alcohol Health and Research World.
Shon, S.P., and Ja, D.Y. Asian families. In: McGoldrick, M., Pearce, J.K., and Giordano, J., eds. Ethnicity and Family Therapy. New York: Guilford Press, 1982. pp. 208–228.
Simonelli R., Ferrigno B. (1993). Alcoholic recovery and the 12 Steps. Winds of Change.
Sisson R.W., Azrin N.H. (1986). Family‐member involvement to initiate and promote treatment of problem drinkers. Journal of Behavior Therapy and Experimental Psychiatry.
Sisson, R.W., and Azrin, N.H. Community reinforcement training for families: A method to get alcoholics into treatment. In: O’Farrell, T.J., ed. Treating Alcohol Problems: Marital and Family Interventions. New York: Guilford Press, 1993. pp. 34–53.
Skinner H.A., Holt S., Schuller R., Roy J., Israel Y. (1984). Identification of alcohol abuse using laboratory tests and a history of trauma. Annals of Internal Medicine.
Sluzki C.E. (2000). Social networks and the elderly: Conceptual and clinical issues, and a family consultation. Family Process.
Spear L. (2000). Modeling adolescent development and alcohol use in animals. Alcohol Research and Health.
Stack, C.B. All Our Kin: Strategies for Survival in a Black Community. New York: Harper and Row, 1974.
Stanton, M.D. An integrated structural/strategic approach to family therapy. Journal of Marital and Family Therapy 7(4):427–439, 1981a.
Stanton, M.D. Strategic approaches to family therapy. In: Gurman, A.S., and Kniskern, D.P., eds. Handbook of Family Therapy: Vol. 1. New York: Brunner/Mazel, 1981b. pp. 361–402.
Stanton, M.D. Breaking away: The use of strategic and Bowenian techniques in treating an alcoholic family through one member. In: Kaufman, E., ed. Power to Change: Family Case Studies in the Treatment of Alcoholism. New York: Gardner Press, 1984a. pp. 253–266.
Stanton, M.D. Fusion, compression, diversion, and the workings of paradox: A theory of therapeutic/systemic change. Family Process 23(2):135–167, 1984b.
Stanton M.D. (1988). Coursework and self‐study in the family treatment of alcohol and drug abuse: Expanding Heath and Atkinson’s curriculum. Journal of Marital and Family Therapy.
Stanton, M.D. The role of family and significant others in the engagement and retention of drug‐dependent individuals. In: Onken, L.S., Blaine, J.D., and Boren, J.J., eds. Beyond the Therapeutic Alliance: Keeping the Drug Dependent Individual in Treatment. NIDA Research Monograph 165. NIH Publication No. 97‐4142. Rockville, MD: National Institute on Drug Abuse, 1997. pp. 157–180.
Stanton M.D., Shadish W.R. (1997). Outcome, attrition, and family‐couples treatment for drug abuse: A meta‐analysis and review of the controlled, comparative studies. Psychological Bulletin.
Stanton, M.D., Todd, T.C., and Associates. The Family Therapy of Drug Abuse and Addiction. New York: Guilford Press, 1982.
Stanton M.D., Todd T.C., Heard D.B., Kirschner S., Kleiman J.I., Mowatt D.T., Riley P., Scott S.M., Van Deusen J.M. (1978). Heroin addiction as a family phenomenon: A new conceptual model. American Journal of Drug and Alcohol Abuse.
Stein, L.I., and Santos, A.B. Assertive Community Treatment of Persons with Severe Mental Illness. New York: W.W. Norton, 1998.
Stein L.I., Test M.A. (1980). Alternative to mental hospital treatment: I. Conceptual model, treatment program, and clinical evaluation. Archives of General Psychiatry.
Steinglass, P. Family therapy: Alcohol. In: Galanter, M., and Kleber, H.D., eds. Textbook of Substance Abuse Treatment. 2d ed. Washington, DC: American Psychiatric Press, 1999. pp. 379–387.
Steinglass, P., Bennett, L.A., Wolin, S.J., and Reiss, D. The Alcoholic Family. New York: BasicBooks, 1987.
Stevens M., Youells F., Whaley F., Linsey S. (1995). Drug use prevalence in a rural school‐age population: The New Hampshire survey. American Journal of Preventive Medicine.
Stith S.M., Rosen K.H., McCollum E.E., Coleman J.U. (1996). The voices of children: Preadolescent children’s experiences in family therapy. Journal of Marital and Family Therapy.
Su S.S., Hoffmann J.P., Gerstein D.R., Johnson R.A. (1997). The effect of home environment on adolescent substance use and depressive symptoms. Journal of Drug Issues.
Substance Abuse and Mental Health Services Administration. Children’s Program Kit: Supportive Education for Children of Addicted Parents. DHHS Publication No. (SMA) 03‐3825. Rockville, MD: Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, 2003.
Sue D. (1997). Multicultural training. International Journal of Intercultural Relations.
Sue, D.W., and Sue, D. Counseling the Culturally Different: Theory and Practice. 3d ed. New York: John Wiley and Sons, 1999.
Sue S., Zane N. (1987). The role of culture and cultural techniques in psychotherapy: A critique and reformulation. American Psychologist.
Sullivan, E., Mino, M., Nelson, K., and Pope, J. Families as a Resource in Recovery from Drug Abuse: An Evaluation of La Bodega de la Familia. New York: Vera Institute of Justice, 2002. http://www.vera.org/publication_pdf/163_250.pdf [Accessed February 11, 2004].
Susser E.S., Lin S.P., Conover S.A. (1991). Risk factors for homelessness among patients admitted to a state mental hospital. American Journal of Psychiatry.
Sutton, C.T., and Broken Nose, M.A. American Indian families: An overview. In: McGoldrick, M., Giordano, J., and Pearce, J.K., eds. Ethnicity and Family Therapy. 2d ed. New York: Guilford Press, 1996. pp. 31–44.
Szapocznik, J., Hervis, O., and Schwartz, S. Brief Strategic Family Therapy. Rockville, MD: National Institute on Drug Abuse, in press.
Szapocznik, J., Hervis, O., and Schwartz, S. Therapy Manuals for Drug Addiction: Brief Strategic Family Therapy for Adolescent Drug Abuse. Bethesda, MD: National Institute on Drug Abuse, 2003. http://165.112.78.61/pdf/Manual5.pdf [Accessed February 11, 2004]. (http://165.112.78.61/pdf/Manual5.pdf)
Szapocznik, J., and Kurtines, W.M. Breakthroughs in Family Therapy with Drug Abusing and Problem Youth. New York: Springer Publishing, 1989.
Szapocznik J., Kurtines W.M., Foote F., Perez‐Vidal A., Hervis O. (1983). Conjoint versus one‐person family therapy: Some evidence for the effectiveness of conducting family therapy through one person. Journal of Consulting and Clinical Psychology.
Szapocznik J., Kurtines W.M., Foote F., Perez‐Vidal A., Hervis O. (1986). Conjoint versus one‐person family therapy: Further evidence for the effectiveness of conducting family therapy through one person with drug‐abusing adolescents. Journal of Consulting and Clinical Psychology.
Szapocznik J., Perez‐Vidal A., Brickman A.L., Foote F.H., Santisteban D., Hervis O., Kurtines W.M. (1988). Engaging adolescent drug abusers and their families in treatment: A strategic structural systems approach. Journal of Consulting and Clinical Psychology.
Szapocznik J., Williams R.A. (2000). Brief strategic family therapy: Twenty‐five years of interplay among theory, research and practice in adolescent behavior problems and drug abuse. Clinical Child and Family Psychology Review.
Tatum, T. Rural women’s recovery program and women’s outreach: Serving rural Appalachian women and families in Ohio. In: Center for Substance Abuse Treatment, ed. Treating Alcohol and Other Drug Abusers in Rural and Frontier Areas. Technical Assistance Publication Series 17. DHHS Publication No. (SMA) 99‐3339. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995. pp. 13–20.
Teachman J.D., Tedrow L.M., Crowder K.D. (2000). The changing demography of America’s families. Journal of Marriage and the Family.
Test, M.A. Training in community living. In: Liberman, R.P., ed. Handbook of Psychiatric Rehabilitation. New York: Macmillan Publishing, 1992. pp. 153–170.
Thomas, E.J., and Ager, R.D. Unilateral family therapy with spouses of uncooperative alcohol abusers. In: O’Farrell, T.J., ed. Treating Alcohol Problems: Marital and Family Interventions. New York: Guilford Press, 1993. pp. 3–33.
Thomas E.J., Santa C., Bronson D., Oyserman D. (1987). Unilateral family therapy with the spouses of alcoholics. Journal of Social Service Research.
Thomas E.J., Yoshioka M.R. (1989). Spouse interventive confrontations in unilateral family therapy for alcohol abuse. Social Casework.
Thomas, E.J., Yoshioka, M., Ager, R., and Adams, K.B. “Experimental outcomes of spouse intervention to reach the uncooperative alcohol abuser: A preliminary report.” Paper presented at the Fifth Congress of the International Society for Bio‐Medical Research on Alcoholism, Toronto, ON, June, 1990.
Toarmino, D., and Chun, C.‐A. Issues and strategies in counseling Korean Americans. In: Lee, C.C., ed. Multicultural Issues in Counseling: New Approaches to Diversity. 2d ed. Alexandria, VA: American Counseling Association, 1997. pp. 233–254.
Trepper T.S., Nelson T.S., McCollum E.E., McAvoy P. (1997). Improving substance abuse service delivery to Hispanic women through increased cultural competencies: A qualitative study. Journal of Substance Abuse Treatment.
Tung M.P. (1994). Symbolic meanings of the body in Chinese culture and “somatization. Culture, Medicine, and Psychiatry.
U.S. Census Bureau. Census 2000 PHC‐T‐10: Hispanic or Latino Origin for the United States, Regions, Divisions, States, and for Puerto Rico. 2000. Washington, DC: U.S. Census Bureau, 2001a. http://www.census.gov/population/cen2000/phc‐t10/phc‐t‐10.pdf [Accessed February 11, 2004].
U.S. Census Bureau. CH‐3: Living Arrangements of Black Children Under 18 Years Old. 1960 to Present. Washington, DC: U.S. Census Bureau, 2001b. http://www.census.gov/population/socdemo/hh‐fam/tabCH‐3.xls [Accessed February 11, 2004].
U.S. Census Bureau. Statistical Abstract of the United States, 2001: The National Data Book. Washington, DC: U.S. Census Bureau, 2001c. http://www.census.gov/prod/2002pubs/01statab/stat‐ab01.html [Accessed February 11, 2004].
U.S. Department of Health and Human Services. Research Shows Needle Exchange Programs Reduce HIV Infections Without Increasing Drug Use. Washington, DC: U.S. Department of Health and Human Services, 1998. http://www.hhs.gov/news/press/1998pres/980420a.html [Accessed February 11, 2004].
U.S. Department of Housing and Urban Development. Martinez Outlines Bush Administration Strategy to Combat Chronic Homelessness: Speech to Homeless Advocates Outlines Coordinated Federal Response to Homelessness. Washington, DC: Department of Housing and Urban Development, 2002. http://www.hud.gov/news/release.cfm?content=pr02‐080.cfm [Accessed February 11, 2004].
Uehara E.S., Takeuchi D.T., Smukler M. (1994). Effects of combining disparate groups in the analysis of ethnic differences: Variations among Asian American mental health service consumers in level of community functioning. American Journal of Community Psychology.
Vaillant, G.E. The Natural History of Alcoholism Revisited. Cambridge: Harvard University Press, 1995.
Vanderbilt University Institute for Public Policy Studies. Homeless Families Program Overview. Washington, DC: Vanderbilt University Institute for Public Policy Studies, 1999. http://www.vanderbilt.edu/VIPPS/CMHP/Public/public.html [Accessed February 11, 2004].
Varley C.K. (1984). Schizophreniform psychoses in mentally retarded adolescent girls following sexual assault. American Journal of Psychiatry.
Vash, C.L. The Psychology of Disability. New York: Springer, 1981.
Wagenfeld, M.O., Murray, J.D., Mohatt, D.F., and DeBruyn, J.C. Mental Health and Rural America: 1980‐1993. An Overview and Annotated Bibliography. NIH Pub. No. 94‐3500. Rockville, MD: Health Resources and Services Administration and National Institute of Mental Health, 1994.
Waldron H.B. (1997). Adolescent substance abuse and family therapy outcome: A review of randomized trials. Advances in Clinical Child Psychology.
Waldron, H.B., Brody, J.L., and Slesnick, N. Integrative behavioral and family therapy for adolescent substance abuse. In: Monti, P.M., and Colby, S.M., eds. Adolescents, Alcohol and Substance Abuse: Reaching Teens Through Brief Interventions. New York: Guilford Press, 2000. pp. 216–243.
Walitzer, K.S. Family therapy. In: Ott, P.J., Tarter, R.E., and Ammerman, R.T., eds. Sourcebook on Substance Abuse: Etiology, Epidemiology, Assessment, and Treatment. Needham Heights, MA: Allyn and Bacon, 1999. pp. 337–349.
Wallace J. (1989). A biopsychosocial model of alcoholism. Social Casework.
Walsh, F. Family therapy: Systems approaches to clinical practice. In: Brandell, J.R., ed. Theory and Practice in Clinical Social Work. New York: The Free Press, 1997. pp. 132–163.
Watzlawick, P., Weakland, J.H., and Fisch, R. Change: Principles of Problem Formation and Problem Resolution. New York: W.W. Norton, 1974.
Weaver, H.N. Native Americans and substance abuse. In: Straussner, S.L.A., ed. Ethnocultural Factors in Substance Abuse Treatment. New York: Guilford Press, 2001. pp. 77–96.
Wegscheider, S. Another Chance: Hope and Health for the Alcoholic Family. Palo Alto, CA: Science and Behavior Books, 1981.
Wermuth L., Scheidt S. (1986). Enlisting family support in drug treatment. Family Process.
Werner E.E. (1986). Resilient offspring of alcoholics: A longitudinal study from birth to age 18. Journal of Studies on Alcohol.
Westermeyer J., Neider J. (1994). Substance disorder among 100 American Indian versus 200 other patients. Alcoholism: Clinical and Experimental Research.
White, J.L. Toward a black psychology. In: Jones, R.L., ed. Black Psychology. 2d ed. Berkeley, CA: Cobb & Henry Publishers, 1980. pp. 5–12.
White, M., and Epston, D. Narrative Means to Therapeutic Ends. New York: W.W. Norton, 1990.
Wilkinson, D. Family ethnicity in America. In: McAdoo, H.P., ed. Family Ethnicity: Strength in Diversity. Thousand Oaks, CA: Sage Publications, 1993. pp. 15–59.
Wilkinson, H. Celebrate the new family: Are “supply mums” and “supply dads” such a bad thing? New Statesman (August 9):21–23, 1999.
Wolin, S.J., and Wolin, S. The Resilient Self: How Survivors of Troubled Families Rise Above Adversity. New York: Villard Books, 1993.
Woods J.H., Winger G. (1995). Current benzodiazepine issues. Psychopharmacology.
Wright, E.M. Substance abuse in African American communities. In: Straussner, S.L.A., ed. Ethnocultural Factors in Substance Abuse Treatment. New York: Guilford Press, 2001. pp. 31–51.
Yates F.E. (1988). The evaluation of a ‘co‐operative counselling’ alcohol service which uses family and affected others to reach and influence problem drinkers. British Journal of Addiction.
Young T.J. (1993). Alcoholism prevention among Native‐American youth. Child Psychiatry and Human Development.
Zeig, J.K., ed. Ericksonian Psychotherapy. New York: Brunner/Mazel, 1985.
Zitzow, D., and Estes, G. The heritage consistency continuum in counseling Native American children. In: American Indian Issues in Higher Education. Los Angeles: American Indian Studies Center, 1981. pp. 133–139.