# Consensus Panel

## Chair

- Edward Kaufman, M.D.
- Editor in Chief
- American Journal of Drug and Alcohol Abuse
- Dana Point, California

## Co‐Chair

- Marianne R. M. Yoshioka, M.S.W., Ph.D.
- Associate Professor
- Columbia University
- School of Social Work
- New York, New York

## Workgroup Leaders

- Mary M. Gillespie, Psy.D., CASAC
- Professor
- Hudson Valley Community College
- Saratoga Springs, New York

- Gloria Grijalva‐Gonzales
- Certified Sr. Substance Abuse Case Manager/Counselor
- San Joaquin County ‐ Office of Substance Abuse
- Allies Project
- Stockton, California

- I. Andrew Hamid, Ph.D., M.S.W., MFT, CSW
- Professor
- Columbia University
- School of Social Work
- New York, New York

- David Rosenthal, Ph.D.
- Director
- La Bodega de la Familia
- Family Justice Center (Drop Center)
- New York, New York

- Daniel Santisteban, Ph.D.
- Research Associate Professor
- University of Miami
- School of Medicine
- Miami, Florida

- Carol Shapiro, M.S.W.
- Executive Director
- Family Justice Center
- New York, New York

## Panelists

- Fred U. Andes, D.S.W., M.S.W., M.P.A., LCSW
- Associate Professor of Sociology
- New Jersey City University
- Jersey City, New Jersey

- Paul Curtin, M.A., CAC, NCAC II
- President
- Alcohol Services, Inc.
- Syracuse, New York

- Jo‐Ann Krestan, M.A., MFT, LADC
- Family Therapist/Writer
- Private Practice
- Surry, Maine

- Eric E. McCollum, Ph.D., LCSW, LMFT
- Professor and Clinical Director
- Virginia Tech Falls Church
- Marriage and Family Therapy Program
- Falls Church, Virginia

- Margaret McMahon, M.T.S., M.S., M.S.W.
- Clinician
- Licensed Certified Social Worker
- Private Practice
- Washington, DC

- Greer McSpadden, M.S.W., LISW
- Director, BHS
- First Nations Community Health Source
- Albuquerque, New Mexico

- William Francis Northey, Jr., Ph.D.
- Research Specialist
- American Association for Marriage and Family Therapy
- Alexandria, Virginia

- Marlene F. Watson, Ph.D.
- Director
- Programs in Couple and Family Therapy
- Drexel University
- Philadelphia, Pennsylvania

- Loretta Young Silvia, M.Ed., Ph.D.
- Associate Professor of Psychiatry
- Wake Forest University School of Medicine
- Department of Psychiatry and Behavioral Medicine
- Winston‐Salem, North Carolina