# Acknowledgments

Numerous people contributed to the development of this TIP (see pp. ix, xii, and appendices E, F, and G). This publication was produced by The CDM Group, Inc. (CDM) under the Knowledge Application Program (KAP) contract, number 270‐99‐7072 with the Substance Abuse and Mental Health Services Administration (SAMHSA), U.S. Department of Health and Human Services (DHHS). Karl D. White, Ed.D., and Andrea Kopstein, Ph.D., M.P.H., served as the Center for Substance Abuse Treatment (CSAT) Government Project Officers. Christina Currier served as the CSAT TIPs Task Leader. Rose M. Urban, M.S.W., J.D., LCSW, CCAC, CSAC, served as the CDM KAP Executive Deputy Project Director. Elizabeth Marsh served as CDM KAP Deputy Project Director. Shel Weinberg, Ph.D., served as the CDM KAP Senior Research/Applied Psychologist. Other CDM KAP personnel included Raquel Witkin, M.S., Deputy Project Manager; Susan Kimner, Managing Editor; Pamela Dronka, former Editor/Writer; Michelle Myers, Editor/Writer; Sonja Easley, Editorial Assistant, and Jason Merritt, Manager of Collateral Products. In addition, Sandra Clunies, M.S., I.C.A.D.C., served as Content Advisor. Jonathan Max Gilbert, M.A., Helen Oliff, B.S., David Sutton, B.A., Catalina Bartlett, M.A., and Randi Henderson, B.A., B.S. served as writers.