# Appendix A -- Bibliography

Abt Associates, Inc. An Evaluation of the Impact of Employment Specialists in Drug Abuse Treatment. DHHS Pub. No. (ADM) 82-1230. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Alcohol, Drug Abuse, and Mental Health Administration. 1982.
American Correctional Association. The Female Offender: What Does the Future Hold?. Laurel, MD: American Correctional Association. 1990.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Substance-Related Disorders. 2nd ed. Chevy Chase, MD: American Society of Addiction Medicine. 1996.
Anderson, D., and Berlant, J. Managed mental health and substance abuse services. In: Kongstvedt, P., ed. Essentials of Managed Health Care. Gaithersburg, MD: Aspen Publications. 1995.
Anglin, M.D., and Fisher, D.G. Survival analysis in drug program evaluation. Part II. Partitioning treatment effects. International Journal of the Addictions. 1987;22:377-387.
Archer, B. Welfare reform's unprecedented success. The Washington Post, August 10. 1998.
Arella, L.R.; Deren, S.; Randell, J.; and Brewington, V. Vocational functioning of clients in drug treatment: Exploring some myths and realities. Journal of Applied Rehabilitation Counseling. 1990;21(2):7-18.
Azrin, N.H., and Besalel, V.A. Job Club Counselor's Manual: A Behavioral Approach to Vocational Counseling. Baltimore, MD: University Park Press. 1980.
Azrin, N.H., and Besalel, V.A. Finding a Job. Berkeley, CA: Ten Speed Press. 1982.
Bandura, A., and Adams, N.E. Analysis of self-efficacy theory of behavior change. Cognitive Therapy and Research. 1977;1:287-310.
Banta, W.F., and Tennant, F. Complete Handbook for Combating Substance Abuse in the Workplace: Medical Facts, Legal Issues, and Practical Solutions. Lexington, MA: Lexington Books. 1989.
Barlow, D.H. Anxiety and Its Disorders: The Nature and Treatment of Anxiety and Panic. New York: Guilford Press. 1988.
Barlow, D.H., ed. Clinical Handbook of Psychological Disorders: A Step-by-Step Treatment Manual. 2nd ed. New York: Guilford Press. 1993.
Barlow, D.H., and Craske, M.G. Mastery of Your Anxiety and Panic. Vol. 2. Albany, NY: Graywind Press. 1994.
Beach, S.R.H.; Sandeen, E.E.; and O'Leary, K.D. Depression in Marriage: A Model for Etiology and Treatment. New York: Guilford Press. 1990.
Becker, R.L. Reading-Free Vocational Interest Inventory (R-FVII). Columbus, OH: Elbern Publications. 1988.
Benshoff, J.J.; Janikowski, T.P.; Taricone, P.F.; and Brenner, J. Alcohol and drug abuse: A content analysis of the rehabilitation literature. Journal of Applied Rehabilitation Counseling. 1990;21(4):9-12.
Bloom, B.; Chesney-Lind, M.; and Owen, B. Women in California Prisons: Hidden Victims of the War on Drugs. San Francisco: Center on Juvenile and Criminal Justice. 1994.
Bolles, R.N. The 1999 What Color Is Your Parachute: A Practical Manual for Job-Hunters and Career-Changers. Berkeley, CA: Ten Speed Press. 1998.
Bonczar, T.P. Characteristics of Adults on Probation, 1995. Bureau of Justice Statistics Special Report. No. NCJ 164267. Washington, DC: U.S. Department of Justice (DOJ), Office of Justice Programs. 1997.
Bourgois, P.I. In Search of Respect: Selling Crack in El Barrio. New York: Cambridge University Press. 1995.
Brown, C.D.; McDaniel, R.; Couch, R.; and McClenahan, M. Vocational Evaluation Systems and Software: A Consumer's Guide. Menomonie, WI: Materials Development Center, Stout Vocational Rehabilitation Institute. 1994.
Budney, A.J., and Higgins, S.T. A Community Reinforcement Plus Vouchers Approach: Treating Cocaine Addiction. Therapy Manuals for Drug Addiction, Manual 2. NIH Pub. No. 98-4309. Rockville, MD: National Institute on Drug Abuse. 1998.
Burtless, G.T. Welfare recipients' job skills and employment prospects. Future of Children. 1997;7(1):39-51.
Canadian Government Employment and Immigration. General Aptitude Test Battery. 1983.
Carroll, K.M. A Cognitive-Behavioral Approach: Treating Cocaine Addiction. Therapy Manuals for Drug Addiction, Manual 1. NIH Pub. No. 98-4308. Rockville, MD: National Institute on Drug Abuse. 1998.
Center for Substance Abuse Treatment. Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 14. DHHS Pub. No. (SMA) 95-3031. Washington, DC: U.S. Government Printing Office. 1995.
Center for Substance Abuse Treatment. Detoxification From Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series, Number 19. DHHS Pub. No. (SMA) 95-3046. Washington, DC: U.S. Government Printing Office. 1995.
Center for Substance Abuse Treatment. Matching Treatment to Patient Needs in Opioid Substitution Therapy. Treatment Improvement Protocol (TIP) Series, Number 20. DHHS Pub. No. (SMA) 95-3049. Washington, DC: U.S. Government Printing Office. 1995.
Center for Substance Abuse Treatment. LAAM in the Treatment of Opiate Addiction. Treatment Improvement Protocol (TIP) Series, Number 22. DHHS Pub. No. (SMA) 95-3052. Washington, DC: U.S. Government Printing Office. 1995.
Center for Substance Abuse Treatment. Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing. Treatment Improvement Protocol (TIP) Series, Number 23. DHHS Pub. No. (SMA) 96-3113. Washington, DC: U.S. Government Printing Office. 1996.
Center for Substance Abuse Treatment. A Guide to Substance Abuse Services for Primary Care Clinicians. Treatment Improvement Protocol (TIP) Series, Number 24. DHHS Pub. No. (SMA) 97-3139. Washington, DC: U.S. Government Printing Office. 1997.
Center for Substance Abuse Treatment. National Treatment Improvement Evaluation Study. (NTIES). Final Report, February. 1997. 1997.
Center for Substance Abuse Treatment. Substance Abuse Treatment and Domestic Violence. Treatment Improvement Protocol (TIP) Series, Number 25. DHHS Pub. No. (SMA) 97-3163. Washington, DC: U.S. Government Printing Office. 1997.
Center for Substance Abuse Treatment. Comprehensive Case Management for Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 27. DHHS Pub. No. (SMA) 98-3222. Washington, DC: U.S. Government Printing Office. 1998.
Center for Substance Abuse Treatment. Naltrexone and Alcoholism Treatment. Treatment Improvement Protocol (TIP) Series, Number 28. DHHS Pub. No. (SMA) 98-3206. Washington, DC: U.S. Government Printing Office. 1998.
Center for Substance Abuse Treatment. Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities. Treatment Improvement Protocol (TIP) Series, Number 29. DHHS Pub. No. (SMA) 98-3249. Washington, DC: U.S. Government Printing Office. 1998.
Center for Substance Abuse Treatment.Continuity of Offender Treatment for Substance Use Disorders From Institution to Community.1998
Center for Substance Abuse Treatment. Cultural Issues in Substance Abuse Treatment. Washington, DC: U.S. Government Printing Office. 1999.
Center for Substance Abuse Treatment. Treatment for Stimulant Use Disorders. Treatment Improvement Protocol (TIP) Series, Number 33. DHHS Pub. No. (SMA) 99-3296. Washington, DC: U.S. Government Printing Office. 1999.
Center for Substance Abuse Treatment. Enhancing Motivation for Change in Substance Abuse Treatment. Treatment Improvement Protocol (TIP) Series, Number 35. DHHS Pub. No. (SMA) 99-3354. Washington, DC: U.S. Government Printing Office. 1999.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues. Treatment Improvement Protocol (TIP) Series, Number 36. DHHS Pub. No. (SMA) 00-3357. Washington, DC: U.S. Government Printing Office. 2000.
Center for Substance Abuse Treatment. Substance Abuse Treatment for Persons With HIV/AIDS. Treatment Improvement Protocol (TIP) Series, Number 37. DHHS Pub. No. (SMA) 00-3410. Washington, DC: U.S. Government Printing Office. 2000.
Comerford, A.W. Work dysfunction and addiction: Common roots. Journal of Substance Abuse Treatment. 1999;16(3):247-253. [pmid: 10194742].
Craighead, W.E.; Craighead, L.W.; and Ilardi, S.S. A Guide to Treatments That Work. New York: Oxford University Press. 1998.
D'Aunno, T., and Vaughn, T.E. An organizational analysis of service patterns in outpatient drug abuse treatment units. Journal of Substance Abuse Treatment. 1995;7(1):27-42.
Dennis, M.L.; Bossert, K.; Brown, A.; Burks, M.; Caddell, J.M., French, M.T.; Giordano, P.B.; Guyett, J.; Ingram, P.; Karuntzos, G.T.; Lucas, R.; Roland, E.J.; Rourke, K.M.; Washington, J.; Watson, M.; and Zarkin, G.A. Training and Employment Program (TEP): Briefing Book. Research Triangle Park, NC: Research Triangle Institute. 1994.
Dennis, M.L.; Karuntzos, G.T.; McDougal, G.L.; French, M.T.; and Hubbard, R.L. Developing training and employment programs to meet the needs of methadone treatment clients. Evaluation and Program Planning. 1993;16:73-86.
Deren, S., and Randell, J. The vocational rehabilitation of substance abusers. Journal of Applied Rehabilitation Counseling. 1990;21(2):4-7.
Droege, R.C. U.S. Employment Service attitude and interest testing for occupational exploration. Journal of Employment Counseling. 1983;20:179-185.
Duncan, G.J. Harris, K.M. and Boisjoly, J. 1997.
Engelhart, P. The Road to Work Recovery: A Training Manual for Substance Abuse Treatment Staff. New York: National Association on Drug Abuse Problems. 1993.
England, G. The meaning of work in the USA: Recent changes. . European Work and Organizational Psychologist. 1991;1:111-124.
Etheridge, R.M.; Craddock, S.G.; Dunteman, G.H.; and Hubbard, R.L. Treatment services in two national studies of community-based drug abuse treatment programs. Journal of Substance Abuse Treatment. 1995;7(1):9-26.
Eyestone, L.L., and Howell, R.J. An epidemiological study of attention-deficit hyperactivity disorder and major depression in a male prison population. Bulletin of the American Academy of Psychiatry and the Law. 1994;22(2):181-193. [pmid: 7949408].
Federal Transit Administration. Use of TANF, WTW, and Job Access Funds for Transportation. U.S. Department of Transportation. 1998.
Feldblum, C.R. The Americans With Disabilities Act: From Policy to Practice. New York: Milbank Memorial Fund. 1991.
Finn, P. Job placement for offenders: A promising approach to reducing recidivism and correctional costs. National Institute of Justice Journal. 1999;(July), 2-11.
French, M.T.; Bradley, C.J.; Calingaert, B.; Dennis, M.L.; and Karuntzos, G.T. Cost analysis of training and employment services in methadone treatment. Evaluation and Program Planning. 1994;17(2):107-120.
French, M.T.; Dennis, M.L.; McDougal, G.L.; Karuntzos, G.T.; and Hubbard, R.L. Training and employment programs in methadone treatment: Client needs and desires. Journal of Substance Abuse Treatment. 1992;9(4):293-303. [pmid: 1336067].
Friedman, L.N. The Wildcat Experiment: An Early Test of Supported Work in Drug Abuse Rehabilitation. DHHS Pub. No. (ADM) 82-782 (reprint). Rockville, MD: National Institute on Drug Abuse. 1978.
Gawin, F.H., and Ellinwood, E.H., Jr. Cocaine and other stimulants: Actions, abuse, and treatment. New England Journal of Medicine. 1988;318(18):1173-1182. [pmid: 3283549].
Gerstein, D.R.; Johnson, R.A.; Harwood, H.J.; Fountain, D.; Suter, N.; and Malloy, K. Evaluating Recovery Services: The California Drug and Alcohol Treatment Assessment (CALDATA). Sacramento, CA: California Department of Alcohol and Drug Programs. 1994.
Goffman, E. Asylums: Essays on the Social Situation of Mental Patients and Other Inmates. Garden City, NY: Anchor Books. 1961.
Hagen, J.L., and Davis, L.V. Women on welfare talk about reform. Public Welfare. 1994;52(3):30-43.
Hall, D.T., and Mirvis, P.H. The Career Is Dead, Long Live the Career: A Relational Approach to Careers. San Francisco: Jossey-Bass. 1996.
Hall, S.M. Drug Abuse Treatment Evaluation: Strategies, Progress, and Prospects. National Institute on Drug Abuse Research Monograph 51. DHHS Pub. No. (ADM) 84-1329. Rockville, MD: NIDA. 1984.
Hanken, K.H. Strategies to promote education, skill development, and career advancement opportunities for low-skilled workers. StateLine. 1998;July 28.
Harlow, C.W. Profile of Jail Inmates, 1996. Bureau of Justice Statistics Special Report. No. NCJ 164620. Washington, DC: U.S. Department of Justice, Office of Justice Programs. 1998.
Harwood, H.; Fountain, D.; Livermore, G.; and The Lewin Group. The Economic Costs of Alcohol and Drug Abuse in the United States: 1992. NIH Pub. No. 98-4327. Rockville, MD: National Institute on Drug Abuse and National Institute on Alcohol Abuse and Alcoholism. 1998.
Haveman, R. From welfare to work: Problems and pitfalls. Focus. 1996;18(1):21-24.
Hawkins, J.D.; Catalano, R.F.; and Miller, J.Y. Risk and protective factors for alcohol and other drug problems in adolescence and early adulthood: Implications for substance abuse prevention (review). Psychological Bulletin. 1992;112(1): 64-105.
Hoffmann, J.P.; Larison, C.; and Sanderson, A. An Analysis of Worker Drug Use and Workplace Policies and Programs. DHHS Pub. No. (SMA) 97-3142. Rockville, MD: Substance Abuse and Mental Health Services Administration, Office of Applied Studies. 1997.
Holland, J.L. The Self-Directed Search. Professional Manual. Tampa, FL: Psychological Assessment Resources. 1985.
Holland, J.L. Vocational Preference Inventory. Tampa, FL: Psychological Assessment Resources. 1985.
Holland, J.L.; Daiger, D.; and Power, P. My Vocational Situation. Palo Alto, CA: Consulting Psychologists Press. 1980.
Holland, J.L., and Gottfredson, G.D. Career Attitudes and Strategies Inventory: An Inventory for Understanding Adult Careers. Tampa, FL: Psychological Assessment Resources. 1994.
Holland, J.L.; Powell, A.B.; and Fritzsche, B.A. The Self-Directed Search: Professional Users Guide. Tampa, FL: Psychological Assessment Resources. 1997.
Hubbard, R.L., and Harwood, H.J. Employment Related Services in Drug Treatment Programs. National Institute on Drug Abuse (NIDA) Treatment Research Report. DHHS Pub. No. (ADM) 81-1144. Rockville, MD: NIDA. 1981.
Joe, G.W.; Chastain, R.L.; and Simpson, D.W. Opioid Addiction and Treatment: A 12-Year Followup. Malabar, FL: Kreiger. 1990.
Johnson, A.; Jones, P.; Kerachsky, S.; and Meckstroth, A. 1998.
Jongsma, A.E., and Peterson, L.M. The Complete Psychotherapy Treatment Planner. New York: John Wiley and Sons. 1995.
Karuntzos, G.T.; Caddell, J.M.; and Dennis, M.L. Gender differences in vocational needs and outcomes for methadone treatment clients. Journal of Psychoactive Drugs. 1994;26(2):173-180. [pmid: 7931862].
Karuntzos, G.T., and Dennis, M.L. Vocational Readiness Screener for Determining Employability. Research Triangle Park, NC: Research Triangle Institute. 1994.
Krantz, G. Critical vocational behaviors. Journal of Rehabilitation. 1971;37:14-16.
Lanehart, R.E.; Clark, H.B.; Rollings, J.P.; Haradon, D.K.; and Scrivner, L. The impact of intensive case-managed intervention on substance-using pregnant and postpartum women. Journal of Substance Abuse. 1996;8:487-495.
Larner, M.B.; Terman, D.L.; and Behrman, R.E. Welfare to work: Analysis and recommendations. The Future of Children. 1997;7(1):4-19.
LeBlanc, A.N. A woman behind bars is not a dangerous man. New York Times Magazine. 1996.
Legal Action Center. The Impact of Managed Care and Utilization Review Practices on Consumer Access to Alcoholism and Substance Abuse Services in New York State. Washington, DC: Legal Action Center, July. 1996.
Legal Action Center. Employment Discrimination and What To Do About It: A Guide for New York Counselors of Former Alcohol and Drug Abusers and Ex-Offenders. Washington, DC: Legal Action Center. 1997.
Legal Action Center. Making Welfare Reform Work: Tools for Confronting Alcohol and Drug Problems Among Welfare Recipients. Washington, DC: Legal Action Center. 1997.
Linehan, M.M. Cognitive-Behavioral Treatment of Borderline Personality Disorder. New York: Guilford Press. 1993.
Livneh, H., and Male, R. Functional limitations: A review of their characteristics and vocational impact. Journal of Rehabilitation. 1993;59(4):44-49.
Long, E.R.; Artese, V.S.; and Clonts, W.L. Wonderlic Basic Skills Test (WBST). Tampa, FL: Psychological Assessment Resources. 1996.
Mannuzza, S.; Klein, R.G.; Konig, P.H.; and Giampino, T.L. Hyperactive boys almost grown up. IV. Criminality and its relationship to psychiatric status. Archives of General Psychiatry. 1989;46(12):1073-1079. [pmid: 2589922].
Maslow, A.H. Motivation and Personality. 3rd ed. New York: Harper and Row. 1987.
Maslow, A.H. Toward a Psychology of Being. 2nd ed. New York: Van Nostrand Reinhold. 1982.
Mauer, M., and Huling, T. Young Black Americans and the Criminal Justice System: Five Years Later. Washington, DC: The Sentencing Project. 1995.
McLellan, A.T. Research on the Treatment of Narcotic Addiction: State of the Art. DHHS Pub. No. (ADM) 83-1281. Rockville, MD: National Institute on Drug Abuse. 1983.
McLellan, A.T.; Grissom, G.R.; Brill, P.; Durell, J.; Metzger, D.S.; and O'Brien, C.P. Private substance abuse treatments: Are some programs more effective than others?. Journal of Substance Abuse Treatment. 1993;10:243-254.
McLellan, A.T.; Grissom, G.R.; Zanis, D.; Randall, M.; Brill, P.; and O'Brien, C.P. Problem-service "matching" in addiction treatment: A prospective study in four programs. Archives of General Psychiatry. 1997;54:730-735.
McLellan, A.T.; Kushner, H.; Metzger, D.; Peters, R.; Smith, I.; Grissom, G.; Pettinati, H.; and Argeriou, M. The Fifth Edition of the Addiction Severity Index. Journal of Substance Abuse Treatment. 1992;9:199-213.
McLellan, A.T.; Luborsky, L.; Cacciola, J.; Griffith, J.; Evans, F.; Barr, H.L.; and O'Brien, C.P. New data from the Addiction Severity Index: Reliability and validity in three centers. Journal of Nervous and Mental Disease. 1985;173:412-423.
McLellan, A.T.; Luborsky, L.; Cacciola, J.; Griffith, J.; McGahan, P.; and O'Brien, C.P. Treatment Research Reports and Monographs Series. Washington, DC: U.S. Government Printing Office. 1985.
McLellan, A.T.; Luborsky, L.; O'Brien, C.P.; and Woody, G.E. An improved diagnostic instrument for substance abuse patients: The Addiction Severity Index. Journal of Nervous and Mental Disease. 1980;168:26-33.
Merrill, J.C. 1994.
Merrill, J.C. Substance Abuse and Federal Entitlement Programs. New York: Columbia University Press. 1995.
Metzger, D.S. 1987.
Meyers, R.J., and Smith, J.E. Clinical Guide to Alcohol Treatment: The Community Reinforcement Approach. New York: Guilford Press. 1995.
Miller, M. Perceptions of Available and Needed Programs by Female Offenders in Delaware. Wilmington, DE: Delaware Council on Crime and Justice. 1990.
Miller, N.S., and Gold, M.S. A neurochemical basis for alcohol and other drug addiction. Journal of Psychoactive Drugs. 1993;25(2):12-28.
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press. 1991.
Molinari, C.; Ahern, M.; and Hendryx, M. Gains from public-private collaborations to improve community health. Journal of Healthcare Management. 1998;43(6):498-510. [pmid: 10338928].
Morash, M.; Bynum T.S.; and Koons, B.A. Women offenders: Programming needs and promising approaches. Research in Brief. 1998;NCJ 171668. Washington, DC: National Institute of Justice.
Mueser, K.T.; Drake, R.E.; and Noordsy, D.L. Antisocial personality disorder, conduct disorder, and substance abuse in schizophrenia. Journal of Abnormal Psychology. 1997;106:473-477.
Mumola, C.J. Substance Abuse and Treatment, State and Federal Prisoners, 1997: Special Report. NJC 172871. Washington, DC: U.S. Department of Justice, Bureau of Justice Statistics. 1999.
National Center on Addiction and Substance Abuse at Columbia University (CASA). No Safe Haven: Children of Substance-Abusing Parents. New York: CASA. 1999.
National Governors' Association (NGA). Current trends and emerging issues in welfare-to-work. NGA Issue Brief. 1997;http://www.nga.org/pubs/issuebriefs/1997/971204welfarework.asp [Accessed December 4.
National Institute on Drug Abuse. DATOS documents dramatic decline in drug abuse treatment services. NIDA Notes. 1997;12(5), September/October.
Nelson, J.C.; Rashid, H.; Galvin, V.G.; Essien, J.D.; and Levine, L.M. Public/private partners: Key factors in creating a strategic alliance for community health. American Journal of Prevention Medicine. 1999;16(3 Suppl.):94-102.
Nightingale, D.S., and Holcomb, P.A. Alternative strategies for increasing employment. The Future of Children. 1997;7(1):52-64. [pmid: 9170732].
Ohio Department of Alcohol and Drug Addiction Services. Cost-Effectiveness Study of Alcohol and Other Drug Treatment Programs. Columbus, OH: Ohio Department of Alcohol and Drug Addiction Services. 1996.
Olson, K., and Pavetti, L.D. Personal and Family Challenges to the Successful Transition From Welfare to Work. Washington, DC: The Urban Institute. 1996.
Parker, R.M., and Szymanski, E.M., eds. Rehabilitation Counseling: Basics and Beyond. Austin, TX: Pro-Ed. 1998.
Pavetti, L.D.; Olson, K.; Nightingale, D.; Duke, A.E.; and Isaacs, J. Welfare-to-Work Options for Families Facing Personal and Family Challenges: Rationale and Program Strategies. Washington, DC: The Urban Institute. 1997.
Platt, J.J. Vocational rehabilitation of drug abusers. Psychological Bulletin. 1995;117(3):416-433. [pmid: 7777647].
Power, P.W. A Guide to Vocational Assessment. Austin, TX: Pro-Ed. 1991.
Prochaska, J.O., and DiClemente, C.C. Transtheoretical therapy: Toward a more integrative model of change. Psychotherapy: Theory, Research, and Practice. 1982;19:276-288.
Rector, R. Drug treatment improves job training effectiveness. Intellectual Ammunition. 1997;September/October.
Rehabilitation Research and Training Center on Drugs and Disability. Substance Abuse, Disability and Vocational Rehabilitation. Wolkstein, E., and Moore, D., eds. Dayton, OH: Rehabilitation Research and Training Center on Drugs and Disability. 1996.
Reuter, P.; MacCoun, R.J.; Murphy, P.J.; Abrahamse, A.F.; and Simon, B. Money From Crime: A Study of the Economics of Drug Dealing in Washington, DC. Santa Monica, CA: RAND. 1990.
Rice, D.P.; Kelman, S.; Miller, L.S.; and Dunmeyer, S. The Economic Costs of Alcohol and Drug Abuse and Mental Illness: 1985. DHHS Pub. No. (ADM) 90-1694. Washington, DC: U.S. Government Printing Office. 1990.
Rosenberg, B. Development of the TOWER system. Vocational and Work Adjustment Bulletin. 1969;2(3): 9-11.
Rowe, H.A. Work Potential Profile (WPP). Canberra, Australia: Australian Council for Educational Research. 1997.
Rubin, S.E., and Roessler, R.T. Foundations of the Vocational Rehabilitation Process. Austin, TX: Pro-Ed. 1995.
Salomone, P.R. Work and Disability: Issues and Strategies in Career Development and Job Placement. Austin, TX: Pro-Ed. 1996.
Salomone, P.R. Career counseling: Steps and stages beyond Parsons. Career Development Quarterly. 1988;36:218-221.
Sampson, J.P.; Peterson, G.W.; Lenz, J.G.; Reardon, R.C.; and Saunders, D.E. Career Thoughts Inventory: Professional Manual. Tampa, FL: Psychological Assessment Resources. 1996.
Schiller, B.R. The Economics of Poverty and Discrimination. 5th ed. Englewood Cliffs, NJ: Prentice Hall. 1989.
Schottenfeld, R.S.; Pascale, R.; and Sokolowski, S. Matching services to needs: Vocational services for substance abusers. Journal of Substance Abuse Treatment. 1992;9(1):3-8. [pmid: 1593662].
Senay, E.C.; Dorus, W.; and Joseph, M.L. Evaluating service needs in drug-abusing clients. International Journal of the Addictions. 1981;16:709-722.
The Sentencing Project. Drug Policy and the Criminal Justice System. Briefing/Fact Sheets. http://www.sentencingproject.org/brief/5047.htm [Accessed February 17. 2000.
Shafer, M.; Parent, W.; and Everson, J. Vocational Rehabilitation and Supported Employment. Baltimore, MD: Brookes. 1988.
Shaw, L.R.; MaGillis, P.W.; and Dvorchik, K.M. Alcoholism and the Americans With Disabilities Act: Obligations and accommodations. Rehabilitation Counseling Bulletin. 1994;38(2):108-113.
Sherman, L.W.; Gottfredson, D.; MacKenzie, D.; Eck, J.; Reuter; P.; and Bushway, S. Preventing Crime: What Works, What Doesn't, What's Promising. Washington, DC: The National Institute of Justice. 1998.
Strawn, J. Substance abuse and welfare reform policy. Welfare Information Network Issue Notes. 1997;1(1).
Substance Abuse and Mental Health Services Administration (SAMHSA). Preliminary Results From the 1997 National Household Survey on Drug Abuse. Fact Sheet. Rockville, MD: SAMHSA. 1998.
Substance Abuse and Mental Health Services Administration (SAMHSA), Office of Applied Studies. National Household Survey on Drug Abuse. DHHS Pub. No. (SMA) 97-3149. Rockville, MD: SAMHSA. 1998.
Suffet, F., and Brotman, R. Employment and social disability among opiate addicts. American Journal of Drug and Alcohol Abuse. 1976;3:387-395.
Syzmanski, E.; Ryan, C.; Merz, M.; Trevino, B.; and Johnston-Rodriguez, S. Work and Disability: Issues and Strategies in Career Development and Job Placement. Austin, TX: Pro-Ed. 1996.
Teplin, L.A.; Abram, K.M.; and McClelland, G.M. Prevalence of psychiatric disorders among incarcerated women. I. Pretrial jail detainees. Archives of General Psychiatry. 1996;53(6):505-512. [pmid: 8639033].
Terkel, S. Working. New York: Ballentine. 1985.
U.S. Department of Health and Human Services (DHHS), Administration for Children and Families, Substance Abuse and Mental Health Services Administration, Office of the Assistant Secretary for Planning and Evaluation (ASPE). Blending Perspectives and Building Common Ground: A Report to Congress on Substance Abuse and Child Protection. Washington, DC: U.S. Government Printing Office. 1999.
U.S. Department of Health and Human Services, Administration for Children and Families. Change in Welfare Caseloads as of September 1998. Washington, DC: U.S. Department of Health and Human Services. 1999.
U.S. Department of Health and Human Services (DHHS), Office of the Assistant Secretary for Planning and Evaluation (ASPE); National Institute on Drug Abuse. Substance Abuse Among Women and Parents. Washington, DC: DHHS/ASPE. 1994.
U.S. Department of Health and Human Services (DHHS), Office of the Assistant Secretary for Planning and Evaluation (ASPE); National Institute on Drug Abuse. Patterns of Substance Use and Program Participation. Washington, DC: DHHS/ASPE. 1994.
U.S. Department of Health and Human Services (DHHS), Office of the Assistant Secretary for Planning and Evaluation (ASPE); the Public Health Service, National Institutes of Health/National Institute on Drug Abuse; and the Substance Abuse and Mental Health Services Administration. Patterns of Substance Use and Substance-Related Impairment Among Participants in the Aid to Families With Dependent Children Program (AFDC). Washington, DC: DHHS/ASPE. 1994.
U.S. Department of Justice (DOJ), Office of Justice Programs. Women in Criminal Justice: A Twenty Year Update. A Special Report from the Coordination Group on Women. Washington, DC: DOJ, October. 1998.
U.S. Department of Justice (DOJ), Office of Justice Programs, Bureau of Justice Statistics. Criminal Offenders Statistics. Washington, DC: DOJ. 1999.
U.S. Department of Justice (DOJ), Office of Justice Programs, Bureau of Justice Statistics. Enforcement. Washington, DC: DOJ. 1999.
U.S. Department of Justice (DOJ), Office of Justice Programs, Bureau of Justice Statistics. Prison and Jail Inmates at Midyear 1998. No. NCJ-173414. Washington, DC: DOJ, March. 1999.
U.S. Department of Justice (DOJ), Office of Justice Programs, Bureau of Justice Statistics. Substance Abuse and Treatment, State and Federal Prisoners, 1997. No. NCJ 172871. Washington, DC: DOJ, January. 1999d.
U.S. Department of Labor. Manual for the USES General Aptitude Test Battery. Section III: Development. Washington, DC: U.S. Government Printing Office. 1970.
U.S. Department of Labor. Manual for the USES Interest Inventory. Minneapolis, MN: Intran Corp. 1981.
U.S. Department of Labor, Bureau of Labor Statistics. Occupational Outlook Handbook, 1998-99 Edition. Washington, DC: U.S. Government Printing Office. 1998.
U.S. Department of Labor, Bureau of Labor Statistics. Occupational Outlook Handbook, 2000-01 Edition. Washington, DC: U.S. Government Printing Office, published annually. http://stats.bls.gov:80/ocohome.htm [Accessed March 19. 2000.
U.S. Department of Veterans Affairs. VA History in Brief. VA Pamphlet 80-97-2. Washington, DC: U.S. Department of Veterans Affairs, Office of Public Affairs. 1997.
U.S. Employment Service. Guide for Occupational Exploration. Washington, DC: U.S. Government Printing Office. 1979.
Vaillant, G.E. A 12-year followup of New York narcotic addicts: IV. Some characteristics and determinants of abstinence. American Journal of Psychiatry. 1966;123:573-585.
Vaillant, G.E. What can long-term followup teach us about relapse and prevention of relapse in addiction?. British Journal of Addiction. 1988;83:1147-1157.
Valpar International Corporation. Manual for MESA '84. Microcomputer Evaluation Screening and Assessment. Tucson, AZ: Valpar International Corporation. 1984.
Vandergoot, D. Placement practices in vocational rehabilitation. . Journal of Applied Rehabilitation Counseling. 1984;15(3):24-28.
Vobejda, B., and Havemann, J. States' welfare shift: Stop it before it starts. The Washington Post. 1998;August 12.
Wellisch, J.; Anglin, M.D.; and Prendergast, M.L. Numbers and characteristics of drug-using women in the criminal justice system: Implications for treatment. Journal of Drug Issues. 1993;23(1):7-30.
Wickizer, T.; Joesch, J.; Longhi, D.; Krupski, A.; and Stark, K. Employment Outcomes of Indigent Clients Receiving Alcohol and Drug Treatment in Washington State. DHHS Pub. No. (SMA) 97-3129. Rockville, MD: Substance Abuse and Mental Health Services Administration. 1997.
Wolkstein, E., and Bausch, R.B. 1998.
Wolkstein, E., and Hastings-Black, D. Handbook on Drug Abuse. Rockville, MD: National Institute on Drug Abuse. 1979.
Wolkstein, E., and Spiller, H. Providing vocational services to clients in substance abuse rehabilitation. Directions in Rehabilitation Counseling. 1998;9:65-78.
Woolis, D.D. Family works: Substance abuse treatment and welfare reform. Public Welfare. 1998;56(1):24-32.
Wright, G.N. Total Rehabilitation. Boston: Little, Brown. 1995.
Young, N.K. Invest in Treatment for Alcohol and Other Drug Problems: It Pays. Washington, DC: National Association of State Alcohol and Drug Abuse Directors. 1994.
Young, N.K. Alcohol and Other Drug Treatment: Policy Choices in Welfare Reform. Rockville, MD: Center for Substance Abuse Treatment. 1996.
Young, N.K., and Gardner, S.L. Implementing Welfare Reform: Solutions to the Substance Abuse Problem. Irvine, CA: Children and Family Futures; and Washington, DC: Drug Strategies. 1997.
Young, N.K.; Gardner, S.L.; and Dennis, K. Responding to Alcohol and Other Drug Problems in Child Welfare: Weaving Together Practice and Policy. Washington, DC: Child Welfare League of America. 1998.
Zadny, J.J., and James, L.F. Studies in Placement. Monograph No. 2, Job Development for the Handicapped. Portland, OR: Regional Rehabilitation Research Institute, School of Social Work, Portland State University. 1977.