# Figure F-2: Federal Sources of Discretionary, Time-Limited Project Grants

Figure F-2: Federal Sources of Discretionary, Time-Limited Project Grants

Figure F-2: Federal Sources of Discretionary, Time-Limited Project Grants

Note : This list is not intended to be comprehensive.

Department of Education

National Institute on Disability and Rehabilitation Research

Office of Special Education and Rehabilitative Services, Rehabilitation Services Administration

Department of Health and Human Services

Administration for Children and Families

Health Care Financing Administration

Health Resources and Services Administration

National Institutes of Health

National Institute on Alcohol Abuse and Alcoholism

National Institute on Drug Abuse

National Institute of Mental Health

Substance Abuse and Mental Health Services Administration

Center for Substance Abuse Prevention

Center for Substance Abuse Treatment

Center for Mental Health Services

Department of Housing and Urban Development

Department of Justice

Executive Office for Weed and Seed

National Institute of Justice Office of Justice Programs

Office of Juvenile Justice and Delinquency Prevention

Department of Labor Department of Transportation

Federal Transit Administration

1 Title VII of the Civil Rights Act (29 U.S.C. §2000e-2000e-17), which prohibits employment discrimination based on race, has been interpreted to outlaw questions about an applicant's arrests. This ruling is based on two premises: (1) Members of minority racial groups are arrested more often than whites, which means that this question tends to disqualify a disproportionate number of minority applicants, and (2) an arrest that has not resulted in conviction of a crime has little value as a test of character. A few States, such as New York, have adopted legislation that offers limited protection to ex-offenders from employment discrimination. Unlike the Federal laws protecting individuals with disabilities, however, the law permits employers to weigh an individual's convictions against a set of factors in determining whether to hire him. Employers can weigh the disability in terms of whether or not the employer believes it means that the applicant cannot fulfill the "essential functions" of the job (and perhaps also that changes to the job situation would fundamentally alter management prerogatives).

2 To learn more about State law--the protections it offers and the available remedies--providers can call the State or local "human rights," "civil rights," or "equal opportunity" agency. Local legal services offices, law school faculties, or bar associations may also have information available or may be willing to provide a lawyer to make a presentation to staff.