# Figure F-1: Federal Funding Sources

Figure F-1: Federal Funding Sources

Figure F-1: Federal Funding Sources

Figure F-1 Federal Funding Sources
Services Provided | Federal Agency | Enabling Rule | Target Populations | Eligibility Requirements for Target Populations | Grantee | Contacts
Alcohol abuse prevention and treatment Substance abuse prevention and treatment Primary prevention activities Administrative costs | DHHS | SAPT Block Grant formula (42 U.S.C. §300) | People with alcohol and substance abuse disorders Special populations (e.g., women) | Substance abuse disorders Pregnant/postpartum women | SSA | SSA
Funding for substance abuse treatment of Medicaid-eligible individuals. This is an optional benefit at the State's discretion. | DHHS/HCFAMedicaid | Title XIX of the Social Security Act (42 U.S.C. §§1396-1396v) | Medicaid-eligible individuals | Medicaid Income Age Participation in other Federal programs Pregnancy status | State departments of health and social services | DOL State HHS
Some substance abuse treatment services if State sets funds aside Job training Transportation Child care | DHHS | Personal Responsibility and Work Opportunity Reconciliation Act of 1996 (P.L. 104-193) | TANF recipients | TANF receipt | Three-quarters of formula funds go to States; one-quarter of formula funds go to local communities | DHHS and welfare contracting
Support services for "hardest to employ" TANF recipients Transportation assistance | DOL | Welfare-to-Work grant provisions of Title IV, Part A of the Social Security Act (P.S. 105-33) | Hardest to employ TANF recipients | TANF receipt | State driven | DOL State HHS
Basic and remedial education Job skills assessment On-the-job training Job search assistance Work experience programs Internships School-to-work transition programs Transportation and relocation assistance | DOL | JTP (29 U.S.C. §201-206) (Note: JTPA is superseded by the Workforce Investment Act of 1998 and will be repealed on 7/1/00.) | Unemployed adults Youth Disabled persons Dislocated workers Native Americans Migrant and seasonal farm workers Veterans | Disadvantaged and disabled individuals | Funds are channeled to States, which oversee the planning and operation of local programs | State DOL
States receive block grants for adult employment, training for disadvantaged youths and families, and literacy Grant establishes a system of "one-stop" centers for job seekers | DOL | Workforce Investment Act of 1998(P.L. 105-220) consolidates more than 60 Federal programs into 3 block grants to States for employment, training, and literacy | Disadvantaged adults and youth | Disadvantaged adults and youth | 85% of funds go to local areas; the remainder for Statewide activities | DOL Employment and Training Division
Substance abuse prevention, intervention, referral, and treatment Job training (to assist prevention efforts) Security improvements in public housing complexes | HUD | Drug elimination, "back to work" efforts Public Housing Drug Elimination Program (42 U.S.C. §11901) | Public housing residents | Public housing residence | Local public housing authorities, which contract with service providers | HUD regional office State and local public housing authorities
Substance abuse disorder assessment and treatment Prescription medications Equipment and accommodation for disabled Transportation Training and secondary education Vocational testing and evaluation | DOE | Vocational Rehabilitation Act (29 U.S.C. §720-728a, 730, 731) Workforce Investment Act of 1998 (P.L. 105-220, §106) | People with disabilities People receiving Supplemental Security Income | People with disabilities; Supplemental Security Income | VR agency designated by State | Varies by State
Foster care Services to prevent child abuse and neglect Substance abuse treatment (often court-ordered) Child care | DHHS | Title IV of the SSA (42 U.S.C. §1862) | Parents in child welfare system (often TANF) | TANF-eligible and those in the child welfare system | State or county child welfare services | Child welfare agency or contractors
State determines benefits package; in some States, adolescents and teen mothers are included | DHHS | Title XXI of the Social Security Act (P.L. 105-33 §4901a) CHIP | Uninsured children (as defined by State) | Uninsured children; sometimes more narrowly defined | Varies by State | State HHS
Child care Transportation Detoxification Substance abuse treatment services< Social services | DHHS | Title XX of the Social Security Act (42 U.S.C. §§1397-1397f) | State determined | State determined | State HHS or subcontractor | State HHS
Substance abuse treatment services Tear down housing Move drugs out, services in | DOJ | "Weed and Seed" | Residents in designated neighborhoods | Law enforcement agencies with local community coalitions | Law enforcement agencies working as part of a community coalition | Executive Office for Weed and Seed of the DOJ
Substance abuse treatment at every point of entry in the criminal justice system Substance abuse treatment services for adjudicated and non adjudicated individuals | DOJ, Office of Justice Programs, Drug Courts Program Office | Violent Crime Control and Law Enforcement Act of 1994 (28 CFR §93) | Adjudicated and non adjudicated individuals | Adjudicated and non adjudicated individuals | Local criminal justice system | DOJ Office of Justice Programs
Counseling Medical and psychological services Job training | DOE, Office of Special Education and Rehabilita-tive Services, Rehabilitation Services Admini-stration | Rehabilitation Act of 1973 (29 U.S.C. §701ff) | Individuals with physical or mental disabilities (priority given to severely disabled) | Individuals with physical or mental disabilities (priority given to severely disabled) | State VR agency | State VR agency
Help States and local communities develop flexible transportation services that connect welfare recipients and other low-income persons to jobs and other employment-related services | DOT | Transportation Equity Act of 1998 (49 U.S.C. §5309) | Welfare recipients, low-income persons | Welfare recipients, low-income persons | States, local communities | DOT Federal Transit Administration
Loans and grants to create jobs, expand business opportunities Support activities for job hunting, such as job training, child care, transportation | HUD, USDA | Empowerment Zone and Enterprise Community Initiative (26 U.S.C. §1391) | Designated EZs or ECs | Within area with local discretion | EZ/EC local coalitions | HUD
Aid in the elimination of slums and blight Meet other urgent community development needs Neighborhood revitalization Economic development Improvement of community facilities and public services | HUD | Housing and Community Development Act of 1974 (42 U.S.C. §5301) | Low- and moderate-income people | Low- and moderate-income people | Entitled communities (metropolitan cities and urban counties) | HUD