# Figure 8-2: Summary of Program Examples

Figure 8-2: Summary of Program Examples

Figure 8-2: Summary of Program Examples

Figure 8-2 Summary of Program Examples
| Safer Foundation (Chicago) | Center for Employment Opportunities (CEO)(New York) | Project RIO (Texas) | Corrections Clearinghouse (CCH) (Washington State)
Original Objectives | To provide vocational training to inmates and to assist them in entering into unions and private industry after release | To develop work crews that could offer day labor employment in neighborhoods where offenders were living | To provide specialized employment services to ex-offenders to reduce recidivism | To coordinate job search activities for adult offenders being released from prison
Program Components | (1) 200-bed work release centers where residents attend nine 90-minute minicourses and basic reading and math skills courses using a small-group, peer-learning approach. (2) The PACE (Programmed Activities for Correctional Education) Institute, a private school that provides basic education and life skills courses (3) A coordinator closely supervises 200 trained volunteers who provide literacy tutoring and 65 who facilitate groups. | (1) CEO assigns ex-offenders to day labor work crews. (2) Orientation includes four all-day job readiness classes and a 90-minute orientation to the work crews. | (1) Funds for a prison school district for life skills courses, job readiness counseling, and help assembling needed documents (e.g., birth certificates, social security cards, school transcripts) (2) A 30-minute orientation to the RIO hotline number and the program that inmates attend on their release day (3) Assessment, placement, and followup services (4) Arrangements for employers to spend a day in prison talking to inmates about job opportunities | (1) Several prerelease job-related courses as well as vocational assessment (2) At the Corrections Center for Women, CCH offers two transition-to-trades initiatives for women (3) CCH contracts with six community agencies and one employment service center to provide job search assistance to adult and juvenile ex-offenders, including ongoing postplacement services ("Ex-O" Program) (4) A college program for ex-offenders in recovery for substance abuse problems
Data/Results | (1) Improved GED scores by an average of 12.5 percent (2) Ninety-one percent of inmates improved basic skills test scores (3) Fifty-nine percent of those who found jobs remained on the job for at least 30 days | (1) Average placement rate of 70 percent (2) Half of those who remained on the job for 1 month were still on the same job at 6 months (3) In 1996, the average hourly wage of placed participants was nearly 50 percent higher than minimum wage | (1) In 1995, almost 74 percent of clients were employed at an average of 21 percent above minimum wage. (2) At 1 year after release, 69 percent were employed, compared with 36 percent of non-RIO parolees. (3) Of minority clients, 66 percent found employment compared with 30 percent of African Americans and 36 percent of Hispanos/Latinos who were not enrolled. (4) Forty-eight percent of RIO clients were rearrested during the year after release, compared with 57 percent of non-RIO parolees. | (1) In 1997 and 1998, 3,082 inmates completed a CCH program. (2) Ex-O contractors enrolled 1,312 ex-offenders, 59 percent of whom found work and 68 percent of whom were still employed after 45 days. (3) Recidivism rate for the Ex-O clients after 1 year was 3 percent, compared with 10 percent for all releasees; after 5 years, recidivism rate was 15 percent for Ex-O clients, compared with 30 percent for all releasees.