# Figure 8-1: A Program That Addresses Women's Issues

Figure 8-1: A Program That Addresses Women's Issues

Figure 8-1: A Program That Addresses Women's Issues

California has been a pioneering State in allowing women inmates with children under the age of 6 to live in community-based facilities. The California Department of Corrections Community Prisoner Mother Program (CPMP) is an innovative program that allows women inmates to strengthen bonds with their children and to reintegrate back into the community as productive and self-reliant individuals. As part of the community re-entry programming, women receive vocational training, job preparedness training, job placement services, referrals, and aftercare services.