# Figure 7-4: Making a Referral to a Vocational or Training Program

Figure 7-4: Making a Referral to a Vocational or Training Program

Figure 7-4: Making a Referral to a Vocational or Training Program

When a substance abuse treatment program refers a client to an outside agency providing vocational services, it has three choices:

1. A counselor can give the client the agency's name, address, and telephone number and urge her to make an appointment.
2. A counselor can call the agency for the client and set up an appointment.
3. The program can invite the agency to interview clients and/or provide services on its premises.

The first option requires no communication between the program and the vocational or training agency; thus, no consent is required. However, the first option does require the client to take the initiative, something she may have difficulty doing. The second option requires the client to sign a consent form permitting the counselor to call the agency and set up an appointment. The third option provides the path of least resistance for the client--she need only present herself to the outside agency on the day it schedules services at the program. By appearing to request services from the outside agency, the client is making a disclosure about her participation in treatment and no consent form is required. However, if the program sets up appointments for clients beforehand, it will need a consent form signed by the client before it can present the list of applicants for services to the vocational or training program. And, as noted above, the substance abuse treatment program must have a proper, signed consent form if it and the vocational or training agency are to communicate in the future about any client they both serve.