# Figure 7-3: Sample Consent Form

Figure 7-3: Sample Consent Form

Figure 7-3: Sample Consent Form

Figure 7-3 Sample Consent Form
Consent for the Release of Confidential Information
I, ___________________________, authorize XYZ Clinic to receive (name of client or participant)
from/disclose to ________________________________________ (name of person and organization)
for the purpose of _______________________________________ (need for disclosure)
the following information__________________________________ (nature of the disclosure)
I understand that my records are protected under the Federal and State Confidentiality Regulations and cannot be disclosed without my written consent unless otherwise provided for in the regulations. I also understand that I may revoke this consent at any time except to the extent that action has been taken in reliance on it and that in any event this consent expires automatically on ____________________ unless otherwise specified below. (date, condition, or event)
Other expiration specifications:
_________________________ Date executed
_________________________ Signature of client
________________________ Signature of parent or guardian, where required