# Figure 7-2: Services Provided Under the Workforce Investment Act of 1996

Figure 7-2: Services Provided Under the Workforce Investment Act of 1996

Figure 7-2: Services Provided Under the Workforce Investment Act of 1996

Core Services include

- Assessment of individuals' skill levels, aptitudes, abilities, and supportive service needs
- Job search and placement assistance and, where appropriate, career counseling
- Information about current job vacancies, the skills those jobs call for, and the kinds of jobs that are generally available in the community, including pay levels and skill requirements
- Information about training available through the one-stop delivery system
- Information about and referral to supportive services, including child care and transportation
- Assistance with establishing eligibility for welfare-to-work activities and financial aid programs for training and education not funded by the Act
- Followup services (including counseling about the workplace) for those placed in unsubsidized employment (º134(d)(2) of P.L. 105-220)

Intensive Services include

- Comprehensive and specialized assessments of the skill levels and service needs of individuals, including diagnostic testing and in-depth interviewing and evaluation to identify employment barriers and appropriate employment goals
- Development of individualized employment plans identifying employment goals, appropriate achievement objectives, and appropriate combinations of services required to achieve employment goals
- Counseling, including group, individual, and career
- Case management for those seeking training services
- Short-term prevocational services to prepare individuals for unsubsidized employment or training (including development of learning, communication, interviewing, and personal maintenance skills and instruction about punctuality and professional conduct) (º134(d)(3) of P.L. 105-220)

Training Services include

- Occupational skills training, including training for nontraditional employment
- On-the-job training
- Programs that combine workplace training with related instruction
- Training programs operated by the private sector
- Skill upgrading and retraining
- Entrepreneurial training
- Job readiness training
- Adult education and literacy activities
- Customized training conducted by an employer or group of employers committed to employing individuals upon successful completion of the training (º134(d)(4) of P.L. 105-220)