# Figure 7-1: Americans With Disabilities Act and Rehabilitation Act Protections

Figure 7-1: Americans With Disabilities Act and Rehabilitation Act Protections

Figure 7-1: Americans With Disabilities Act and Rehabilitation Act Protections

Figure 7-1 Americans With Disabilities Act and Rehabilitation Act Protections
Alcohol | | | Illegal drugs
| Current abuse | Recovering | Current abuse* | Recovering
Educational or Training Program | Individuals qualified for services are protected | Protected | Protection limited to health and rehabilitation services | Individuals qualified for services are protected
--Exceptions | Individuals are not protected if; - Their alcohol abuse is so severe that they no longer meet the eligibility requirements.; - They pose a significant risk to health or safety of others that cannot be eliminated by service modification or auxiliary aids/services. | No Exceptions | Substance abuse treatment programs may expel clients who continue to use illegal drugs while attending the program. | Individuals are not protected if they pose a direct threat to the health or safety of others. Service providers may administer drug tests to ensure that an individual with a history of illegal drug use is no longer using illegal drugs.
Employment | Individuals qualified for the job are protected if they can perform job duties without posing a threat to health, safety, or property. | Protected | No Protection | Individuals qualified for the job are protected if they; - Participate in a supervised rehabilitation program and are no longer using illegal drugs; - Have successfully completed treatment and are no longer using illegal drugs
--Exceptions | See box above. | No Exceptions | Not Applicable | Employer may administer drug testing to ensure that an individual with a history of illegal drug use is no longer using.
*Current abuse is defined as the illegal use of drugs that occurred recently enough to conclude that it is still a problem.