# Figure 6-1: Agency Self-Assessment Categories

Figure 6-1: Agency Self-Assessment Categories

Figure 6-1: Agency Self-Assessment Categories

Figure 6-1 Agency Self-Assessment Categories
Client | Agency Mission | "Agency Fit" | Endpoints
- Demographics; - Culture; - Family; - Trends; - Focus groups; - Client feedback; - Inclusion of clients in planning; - Disability issues | - Capacity; - Staffing; - Cultural competence; - Readiness for collaboration; - Accountability; - Resources; - Technological capability; - Desired outcome; - Client centeredness; - Service needs | - Analyze agency's service delivery profile versus what clients need; - Choose to provide services in-house or by referral; - Identify community resources and partners; - Build relationships; - Changes in organizational structure; - Specialization and market segmentation | - Sustainable employment; - Better client outcomes; - Improved community conditions; - Multiple access points