# Figure 5-3: Characteristics of Authentically Connected Referral Networks

Figure 5-3: Characteristics of Authentically Connected Referral Networks

Figure 5-3: Characteristics of Authentically Connected Referral Networks

- Multiple agencies work as equal partners with each other and with the client; referring agencies make the initial contact to the referral source and keep abreast of client progress.
- Clients and agencies have mutual responsibility and trust; interagency accountability and data sharing exists.
- Communication mechanisms for timely information dissemination are accessible to all agencies and stakeholders.
- The full range of stakeholders is identified, including local community services, and feedback is elicited from all of them.
- Relationships among providers are collaborative and flexible in the assumption of multiple job tasks related to client needs.
- The network is client-, vision-, and mission-driven.
- Change and growth of the referring organization are demonstrated as a result of the referral process; dynamic network.
- The network is open to new paradigms, approaches, use of technology on behalf of clients (e.g., electronic portfolios), and individualization of client treatment plans and services.
- There is ongoing provider training and involvement in continuing education and staff development.
- Shared assessment of network effectiveness is ongoing.
- Cross-training of staff among collaborating agencies is ongoing.
- Accountability is results- and progress-based, with interagency negotiation of shared outcomes.
- The referral process is concurrent.