# Figure 5-2: Steps for Establishing an Authentically Connected Network

Figure 5-2: Steps for Establishing an Authentically Connected Network

Figure 5-2: Steps for Establishing an Authentically Connected Network

The Consensus Panel developed the concept of authentically connected networks, which include the following steps to their establishment:

1. Determine the services that are available in the local area by developing an updated inventory and by resource mapping.
2. Hold discussions with agencies identified as potential collaborators. Discussions can include topics such as the following:
  - Emphasis on the benefits of collaboration
  - Cross-training of staff
  - How the other agency conducts business (e.g., "turf" issues)
3. Develop working agreements or memorandums of understanding between collaborators to organize information sharing and communicate respective roles.
4. Determine the agency's criteria for accepting clients (e.g., what types of clients and levels of severity do they accept?).
5. If warranted, establish a partnership with the agency, as well as agreements regarding the flow of information and feedback between the agencies to ensure provider accountability.