# Figure 4-3: Focus on Client Outcomes: The Future for Substance Abuse Treatment Providers

Figure 4-3: Focus on Client Outcomes: The Future for Substance Abuse Treatment Providers

Figure 4-3: Focus on Client Outcomes: The Future for Substance Abuse Treatment Providers

CSAT is developing client outcome evaluations that will be disseminated to State and local governments and treatment providers. With these tools, treatment programs can measure their effectiveness and make comparisons on a regional and nationwide basis (http://www.samhsa.gov/csat/topps/default.htm). A substantial initiative by CSAT, the two Treatment Outcome Performance Pilots (TOPPS I and II), which involve 14 and 19 States, respectively, is developing and pilot testing instruments and measures of substance abuse treatment outcomes. These measures will examine changes in several domains including employment, substance use, health status, psychological function, legal status, and family and social relationships. These domains represent consensus among States on the areas where substance abuse treatment is expected to result in changes. Treatment providers will need to address these domains via on- or offsite programming or referrals in order to remain competitive for Federal funding for substance abuse treatment programs.