# Figure 4-2: Job Clubs

Figure 4-2: Job Clubs

Figure 4-2: Job Clubs

A job club can be established in most treatment settings--i.e., high-, medium-, or low-structure programs. However, outpatient programs may find them particularly useful for helping clients obtain jobs with a low investment of staff time. Some job clubs are run by a staff person, but most are organized and operated by clients with a staff person in the role of a consultant.

The job club is a behavioral approach to job finding that is based on research showing that the difficulties faced by most job seekers often involve problems of learning, motivation, and the maintenance of behavior--problems for which the behavioral approach should be most relevant (Azrin and Besalel, 1982). This multistep approach, in which job seeking is regarded as full-time employment, provides a systematic method for conducting a job search. The group context provides important social support to members engaged in the stressful process of finding a job.

To establish a job club, the substance abuse treatment program provides daily newspapers and other current sources of job information and office equipment (e.g., copy machine, typewriter, computer) and supplies. A phone line or lines reserved for job club members and an answering machine help them contact potential employers and allow them to receive messages. The program also can obtain a post office box for members' mail from prospective employers. It is important to remember that some clients may not have a permanent address or phone number and that the person who answers the phone at their home may give a poor impression to the employer or may fail to take messages reliably. Job club members thus use the facility as a home base for conducting their search. Job clubs tend to become part of the treatment milieu and to integrate themselves into programs. There is a natural confluence of substance use disorder and vocational issues in these groups.

The Internet has now become a good resource for job hunting. The cost of a computer and modem may no longer be prohibitive for most programs and may be a good investment if it improves clients' vocational outcomes. In addition, the computer skills that clients gain in their job search may help them on the job.