# Figure 4-1: Steps for Planning an Integrated Program

Figure 4-1: Steps for Planning an Integrated Program

Figure 4-1: Steps for Planning an Integrated Program

- Modify mission statement to incorporate vocational goals for clients.
- Encourage all administrative, support, and treatment staff to embrace vocational programming as an essential component for all clients--on an equivalent level of importance with abstinence.
- Perform a needs assessment of current and past clients to identify what vocational services are most needed.
- Use needs assessment results to identify, develop, and deliver vocational services that make the most sense for the agency, clients, and community.
- Hire a vocational specialist or retool/upgrade existing staff to handle vocational counseling responsibilities.
- Develop vocational counseling competencies in all treatment staff.
- Develop and provide necessary vocational support materials (e.g., employment library, computer with Internet access, training materials for job-seeking skills).
- Integrate vocational outcomes into accountability studies when following up with former clients.