# Figure 3-2: Answering Questions Related to Substance Use History-A Sample Scenario

Figure 3-2: Answering Questions Related to Substance Use History-A Sample Scenario

Figure 3-2: Answering Questions Related to Substance Use History-A Sample Scenario

Interviewer: I noticed that none of these jobs lasted more than 18 months, and most were only a few months.

Client: Yes, a couple of years ago I had problems at a couple of jobs. I think it was partly a question of immaturity. I just wasn't ready to take things seriously.

Interviewer: I also noticed that you haven't been working for the past year. What have you been doing?

Client: I decided I had to get my life together. I'd started using drugs and ended up getting arrested. The court gave me a choice and I took the opportunity to go into drug treatment. I learned a lot about myself and also about working. At the treatment program I volunteered to work in the office.

Interviewer: Do you have any convictions?

Client: Yes, one conviction for drug sale and possession while I was using drugs. I did have problems earlier, but at the drug treatment center I found that I really enjoyed working in the office doing data entry, filing, and answering the phones.

Source: Adapted from Englehart, 1993.