# Figure 3-1: Early-Stage Vocational Issues and Approaches

Figure 3-1: Early-Stage Vocational Issues and Approaches

Figure 3-1: Early-Stage Vocational Issues and Approaches

Psychosocial--Spiritual Values

- Explore alternatives to a substance-using lifestyle and personal value system.
- Explore goals, interests, abilities, strengths, weaknesses, and personal values.
- Learn to consider personal and spiritual needs.
- Identify and acknowledge specific talents.
- Develop the concepts of lifestyle change and psychosocial development.
- Have a stable home and intact family; receive regular paychecks.
- Examine the relationship of substance abuse to other life issues.
- Consider ways to achieve positive parenting, good health, and economic independence from welfare and other support systems.
- Revise one's self-concept in relation to independent functioning at home, school, and work.
- Develop a positive outlook.

Activities of Daily Living

- Learn effective socialization skills.
- Interact without the use of drugs, with people who have not used drugs.
- Engage in activities of daily living.
- Begin to incorporate more healthful habits into daily living.
- Learn appropriate dress, hygiene, walk, talk, and eye contact.
- Learn to manage money.
- Open and maintain bank accounts, budget, and save money.
- Change living situation, if necessary.
- Acquire stable housing away from people currently using drugs; reunite with spouse, parents, or children.
- Check for any outstanding arrests on the client's record and follow up on results.
- Clean up legal records.
- Increase independence and responsibility.
- Assume responsibility for managing money and solving problems.
- Improve communication.
- Talk to new people in new ways.
- Learn to structure and be responsible for time.
- Manage time, calendar, appointments.
- Organize documents, e.g., social security card, birth certificate, military discharge papers, driver's license, diploma, training certificates.
- Get credentials in order and ready to present.
- Consider spirituality as a part of daily living.
- Determine sources for spiritual expression.

Education

- Evaluate educational level, skills, and potential.
- Take tests, assess deficits, plan for remediation if required.
- Examine attitude toward school.
- Highlight positive points.
- Consider longer term educational and vocational goals.
- Consider benefits of further education.

Vocational Skills

- Evaluate vocational level.
- Take tests; engage in a situational assessment.
- Evaluate courses that have been taken; differentiate from courses that have been completed.
- Reexamine prior training and what is still current.
- Consider current vocational skills and their potential for employment.
- Perform skills assessment.
- Examine desires for training.
- Consider why further training is necessary; consider in the context of specific goals.

Employment

- Develop an understanding of the world of work.
- Read career literature; visit work sites.
- Adopt an identity as a worker.
- Explore opportunities to be productive.
- Examine work experiences for past successes and failures.
- Develop a realistic picture of accomplishments and problems.
- Consider potential for transferability of skills.
- Compare skills to job demands.

Source: Adapted from Rehabilitation Research and Training Center on Drugs and Disability, 1996.