# Figure 2-10: Basic Materials for a Vocational Reference Library

Figure 2-10: Basic Materials for a Vocational Reference Library

Figure 2-10: Basic Materials for a Vocational Reference Library

VR counselors use a variety of resources to help clients find jobs. The following is a list of basic materials that a counselor should have available. Although not all programs can afford an Internet hookup to access online employment-related information, they should identify locations where clients can obtain Internet access, such as schools and public libraries.

DOL Documents

- Guide for Occupational Exploration
- Dictionary of Occupational Titles
- Occupational Outlook Handbook

Local Resources

- Local newspaper classified ads
- Local telephone directories
- Catalog of employer profiles
- Contact information (address, phone number of personnel department) of
  - The largest employers in the area
  - The employers who hire the largest number of local workers
  - The fastest growing local employers
  - Employee Assistance Programs
- Mentor lists by employer
- Public transportation routes and schedules
- Course catalogs describing majors and programs in local technical schools, community colleges, and universities

Employment-Related Publications

- College Placement Annual
- National Business Employment Weekly
- The Professional and Trade Association Job Finder
- The National Job Market
- The National and Regional Job Bank
- Career Guide to Professional Associations
- What Color is Your Parachute: A Practical Guide for Job-Hunters & Career-Changers

Other Resources

- Materials from the local Chamber of Commerce
- Materials from the local Job Service
- Access to Web sites such as America's Job Bank (www.ajb.dni.us)
- State economic development Web sites for access to State and national job bank databases