# Figure 2-8: Combating Alcohol and Drugs Through Rehabilitation and Education (CADRE)

Figure 2-8: Combating Alcohol and Drugs Through Rehabilitation and Education (CADRE)

Figure 2-8: Combating Alcohol and Drugs Through Rehabilitation and Education (CADRE)

Limited Case Management/Rehabilitation Support for a Public Housing Community

Fourteen CADRE centers provide prevention and intervention services, operating in 12 Chicago Housing Authority (CHA) developments. Each conducts intake assessment and makes referrals for substance abuse treatment for the community and helps residents to move toward self-sufficiency. As part of these services, residents may receive vocational services on a voluntary basis. Participants are self-referred as a result of flyers distributed door to door or are referred by various social service agencies that work with CHA residents. Each center has a director, one case manager (who is a State-certified alcohol and drug counselor), two prevention specialists, and a general clerk. Programs are funded by the U.S. Department of Housing and Urban Development's Public Housing Drug Elimination Program through a grant to CHA's in-house employment and training program

The CADRE centers make available the following vocational services:

- Job readiness programs that teach participants how to write a résumé, how to look for a job, how to dress for a job, and similar skills
- Job fairs where local businesses take applications and résumés
- Recovery support groups (not geared specifically to employment)
- Access to job-hunting resources such as a telephone, fax machine, computers, and the Internet
- Job training provided through outside consultants