# Figure 2-7: The Michigan Drug Addiction and Alcoholism Referral and Monitoring Agency: A Case Management Model

Figure 2-7: The Michigan Drug Addiction and Alcoholism Referral and Monitoring Agency: A Case Management Model

Figure 2-7: The Michigan Drug Addiction and Alcoholism Referral and Monitoring Agency: A Case Management Model

The Michigan Drug Addiction and Alcoholism Referral and Monitoring Agency (DAARMA) operated under Michigan Rehabilitation Services of the Michigan Jobs Commission until it was eliminated by changes in Social Security and Medicaid. The program served clients receiving Supplemental Security Income who had substance use disorders in addition to other disabilities. Its purpose was to help these clients return to the workforce by ensuring that they had the tools necessary to achieve full rehabilitation and self-sufficiency. This program description is retained because it has many transferable elements.

The program was a three-way partnership between the alcohol and drug counselor, DAARMA, and the vocational rehabilitation services agency. The partners were cross-trained: the State treatment provider agency gave a 6-week intensive training program on substance use disorders for all staff and in turn received training on Medicare rules and on the counseling rehabilitation model. Written agreements documented the partnership. Collaborating agencies made joint decisions on the appropriate timing for the introduction of vocational rehabilitation services. Services generally were introduced as soon as the clients were "clean" and their condition stabilized. The time required for the referral and monitoring process in the Michigan program ranged from 2 to 5 years. The program operated on several principles:

- Careful, comprehensive recovery plans focusing on full rehabilitation and a return to the workforce are essential if the program is to be successful and cost-effective.
- The effectiveness of a recovery plan is only as good as the quality of partnership between the beneficiary's therapist and the referral and monitoring agency counselor.
- For the treatment plan to be successful, the beneficiary must be an active partner in the accomplishment of his own recovery and must be held accountable for his actions.

The case management program included the following elements:

- A preliminary intake to determine clients' needs. Based on the intake results, some clients were referred to a residential program for detoxification.
- Counseling to ensure that clients understood the program's benefits and the sanctions that could be imposed for noncompliance.
- Periodic progress reports involving the clinician and, for corrections clients, the corrections officer.
- Individualized referral to, and coordination of, all services needed to sustain the client's full recovery and rehabilitation (i.e., substance use, physical and/or mental health treatment, habilitation and rehabilitation services, other supportive social services).
- Tools to monitor compliance, including drug testing.

Compliance issues included the following:

- A distinction between noncompliance and relapse. A client who relapsed might continue to receive benefits while attempting to return to treatment, whereas a client who missed appointments regularly might have her cash benefits temporarily suspended. The ability to suspend benefits gave the program a high success rate.
- Loss of 1 month's benefits the first time a client was noncompliant, 2 months of checks for the second noncompliance, and 3 months of checks for the third noncompliance (which seldom occurred).
- During the first year of the program, 53 percent of the participants were noncompliant; however, 72 percent of them returned within 30 days after losing their first checks.

Social Security funded the case management and monitoring function, Michigan Jobs Commission Rehabilitation Services funded the cost of rehabilitation services, and Medicaid funded treatment services. The DAARMA's case management cost per case was $350 per year. One month's benefit check for one individual without dependents was $457. Thus, successful rehabilitation saved the General Fund a minimum of $5,500 per year, per case, in cash benefits. In cases of noncompliance, 1 month's benefit suspension ($457) saved the cost of case management of a case for an entire year. The average cost of rehabilitation services for substance use disorder clients averaged about $1,200 per case.