# Figure 2-6: Vocational Opportunities of Cherokee, Inc.: Rehabilitation Facility Providing Primarily Onsite Services

Figure 2-6: Vocational Opportunities of Cherokee, Inc.: Rehabilitation Facility Providing Primarily Onsite Services

Figure 2-6: Vocational Opportunities of Cherokee, Inc.: Rehabilitation Facility Providing Primarily Onsite Services

Vocational Opportunities of Cherokee, Inc., offers both supported and sheltered employment for Native Americans with severe disabilities. Clients are referred to the program by social welfare programs; alcohol and drug treatment providers; medical treatment providers; the Women, Infants, and Children Program; and other sources.

Following an assessment, the individual reviews job descriptions and chooses a field of work. Detailed evaluations of the individual's capabilities, if needed, can take up to 18 months. All clients receive a basic training program that includes commonly needed skills, such as conflict resolution and grooming. The client then receives appropriate training in the chosen field and to enhance his functional capabilities. He begins with jobs requiring lower dexterity and skill and moves up to more complex jobs as capabilities increase.

The program includes the following services:

- Evaluation
- Counseling and guidance
- Physical and mental restoration
- Culturally appropriate social activities for the client and her family
- Vocational and other training services
- Transportation
- Services to the family members of the client
- Interpreter and note-taking services for the deaf
- Readers, rehabilitation teachers, and note-taking for the blind
- Telecommunication, sensory, and other technological devices
- Recruitment and training services for public service employment
- Placement and suitable employment
- Postemployment services to enable the client to maintain, regain, or advance in employment
- Occupational licenses, tools, equipment, initial stocks, and supplies
- Rehabilitation engineering services; other goods and services

The program employs three counselors, a job coach, and three trainer/managers. It is funded by the State VR agency and by tribal funds. The industrial training floor is operated through contracts with private employers. Some clients also perform contract work, such as grounds care for Federal buildings.