# Figure 2-5: Job Search Resources: America's Job Bank on the Internet

Figure 2-5: Job Search Resources: America's Job Bank on the Internet

Figure 2-5: Job Search Resources: America's Job Bank on the Internet

America's Job Bank (www.ajb.dni.us) is a partnership between the DOL and State-operated employment services. This computerized network links State employment service offices to provide jobseekers with the largest pool of active job opportunities available anywhere, plus nationwide exposure for their résumés. For employers it provides rapid, national exposure for job openings and an easily accessed pool of candidates. The AJB Web site is available on computer systems in public libraries, colleges and universities, high schools, shopping malls, and other public places.

Every day, AJB receives new job listings from the States, and the Internet database is updated each night. On average, more than 5,000 new jobs are received daily from the States. Also, thousands of employers enter their jobs directly into the system in real time. Typically, more than 3,000 new jobs are received directly from employers daily.

In addition to the AJB, there are three other sections to explore on this Web site:

- America's Talent Bank (www.ajb.dni.us). This is a nationwide electronic résumé system. Jobseekers enter résumés into this national network, which is then searched by employers for workers who meet their needs.
- America's Career InfoNet (www.acinet.org). This is a comprehensive source of occupational and economic information. It contains information about general outlook, wages, trends, State profiles, and a resource library.
- America's Learning eXchange (www.alx.org). This is an online source for training and education resources. Jobseekers can find a myriad of training opportunities, including traditional classroom-based training, leading-edge distance learning, Web-based instruction, and multimedia instructional materials (e.g., CD-ROM, video).