# Figure 2-4: Prevocational Counseling Activities

Figure 2-4: Prevocational Counseling Activities

Figure 2-4: Prevocational Counseling Activities

Psychosocial-spiritual development

- Keep a diary of daily activities.
- Participate in role-playing exercises (e.g., for developing interpersonal communication skills, expressing needs and wants without appearing demanding).
- Complete values clarification, skills assessment, and personal traits exercises.

Career exploration

- Generate an autobiography on vocational and educational experiences.
- Visit community resources, including libraries, stores, businesses.
- Read newspapers for a specific purpose (e.g., employment trends, want ads).
- Watch educational and interactive programs to stimulate discussion and practice new behavior.

Structured activity

- Take a battery of vocational tests.
- Pursue and perform volunteer assignments.
- Take continuing education courses to determine and validate interests.
- Write a résumé.

Source: Adapted from Rehabilitation Research and Training Center on Drugs and Disability, 1996.