# Figure 2-3: Assessment Tools

Figure 2-3: Assessment Tools

Figure 2-3: Assessment Tools

Figure 2-3 Assessment Tools
Screening Vocational Interests | Measures/Approaches (not all-inclusive)
Categories of interests | - Geist Picture Interest Inventory; - Kuder Occupational Interest Survey; - Reading-Free Vocational Interest Inventory; - The Self-Directed Search; - Strong Interest Inventory; - Vocational Preference Inventory Interest Checklist; - Wide Range Interest Opinion Test
Vocational functioning | - Addiction Severity Index; - Career Attitudes and Strategies Inventory™; - Career Thoughts Inventory™; - My Vocational Situation; - Wonderlic Basic Skills Test; - Work Potential Profile
Functioning in particular areas related to employability | - Addiction Severity Index; - Employability evaluation; - Employability plan; - Interview information; - Placement readiness checklist; - Previous work experience; - Readiness planning checklist
Emotional functioning | - Interview information; - Tennessee Self-Concept Scale; - The Psychological Screening Inventory; - Verified work history
Intellectual and aptitude functioning | - Addiction Severity Index; - Adult Basic Learning Examination (ABLE); - Educational experience and records; - General Aptitude Test Battery (GATB); - Microcomputer Evaluation, Screening, and Assessment (MESA); - Minnesota Clerical Test; - Peabody Picture Vocabulary Test; - Revised Beta Examination; - Slosson Intelligence Test; - Wechsler Adult Intelligence Scale (WAIS-R); - Wide Range Achievement Test (WRAT)
Source: Adapted from Power, 1991.