# Figure 2-1: Vocational Services Provided to a Residential Treatment Facility

Figure 2-1: Vocational Services Provided to a Residential Treatment Facility

Figure 2-1: Vocational Services Provided to a Residential Treatment Facility

The Virginia Department of Rehabilitative Services provides a full-time VR counselor (perceived by residents as a staff member) to support the integration of vocational strategies into residential therapeutic communities. The counselor works closely with the treatment provider, who collaborates in the development of a VR plan. Clients are referred to the counselor for planning and assessment, which include the administration of aptitude tests that often uncover learning disabilities. An array of services, listed below, is then provided based on the client's individual needs.

- Vocational evaluation, including aptitude, skill level, and interest testing
- Research on jobs of interest to clients and help in arranging informational interviews, along with career counseling
- Referral to training and education or apprenticeship programs
- A week-long program in job-seeking skills, including role-playing and videotaped interviews
- An informal job club with ongoing group sessions to support people looking for work; participants keep a log of their accomplishments and discuss the problems related to reentering the workforce
- Employer outreach and marketing to raise awareness of the availability of this pool of prospective employees
- Job placement services that allow for funding of on-the-job training experiences and tax credits for employers
- Assistance in purchasing work clothes or tools required for entry into a job
- After employment, a "reentry support" group that meets at night during a work adjustment period