# Figure 1-2: Strategies for Promoting Employment

Figure 1-2: Strategies for Promoting Employment

Figure 1-2: Strategies for Promoting Employment

Job Placement Strategies

- Job search assistance, either in a group setting or through one-on-one counseling or coaching, sometimes through "job clubs" with workshops, access to phone banks, and peer support.
- Self-directed job search, where individuals search and apply for jobs on their own. Sometimes individuals must submit a log of their job contacts.
- Job development and placement, where program staff members identify or develop job openings for participants. Counselors refer individuals to openings, often using computerized job banks. In more intensive models, staff members develop relationships with specific firms, gaining knowledge of potential job openings or commitments to hire through the program.

Job Training Strategies

- Classroom occupational training, by training or educational institutions such as community colleges or vocational schools, community-based organizations, or nonprofit or for-profit training centers. Training may include formal postsecondary programs leading to certification or licensing in a particular occupation.
- On-the-job training with public or private sector employers, who usually receive a subsidy to cover a portion of the wages paid during the training period. The employer subsidy may be drawn from welfare or food stamp payments that otherwise would have been paid to the individual recipient.
- Use of a mentor, who provides support to the client within the work setting. A mentor could be someone who went through substance abuse treatment and is now working.

Broad Education Strategies

- Remedial education, such as preparation for the general equivalency diploma (GED), basic skills instruction in reading and mathematics, or English-language classes for persons whose primary language is not English, and computer-skills building.
- Postsecondary degree programs (e.g., associate's or bachelor's degree), generally financed by grants, Federal loans, or scholarships.

Mixed Strategies

- Vocational training plus basic skills, either in the workplace or in instructional centers/classes.
- Supported work experience, with pre-employment preparation, assignment to public jobs, and gradually increasing hours and work responsibility combined with ongoing counseling, education, and peer support.

Source: Nightingale and Holcomb, 1997.