# Figure 1-1: Challenges to Employment

Figure 1-1: Challenges to Employment

Figure 1-1: Challenges to Employment

Figure 1-1 Challenges to Employment
Client Obstacles
Personal; - Substance use (substances used, history and pattern of use, relapse, associated problems); - Mental or physical disabilities (psychiatric comorbidity, physical or medical condition, neuropsychiatric disability, cognitive disabilities, HIV/AIDS); - Deficits in education and skills (education level, learning disability, literacy, language, computer knowledge, obsolete or low-level job skills, little or no work experience); - At-risk history (developmental, familial employment, employment, criminal, loss of parental rights); - Unrealistic expectations and attitudes (toward job demands, work habits, authority, capability for self-sufficiency, personal competencies, change, failure, impulse control, delayed gratification); - Inadequate income (for clothing, food, transportation, housing, child care, job-related equipment); - Work disincentives (from welfare-based income, illicit activities, relatives); - Discontinuation of health benefits; - Crisis lifestyle (illnesses, children's illnesses, violent community, numerous family tragedies and deaths, children's school problems); - Learned helplessness or dependence taught to clients over the years; - "First things first" approach where the client is conflicted about seeking employment and instead encouraged to focus exclusively on sobriety (often this approach is used by 12-Step programs); Attitudes; - Negative attitudes toward vocational rehabilitation; - Negative attitudes toward disability; Interpersonal; - History of violence or abuse (e.g., domestic, physical, sexual, and psychological abuse; criminal activity); - Competing family responsibilities (e.g., child or elder care, disabled family members or relatives); - Inadequate social supports (e.g., spousal, familial, peer group, community, institutional); - Lack of positive modeling (e.g., peer group, familial/parental, societal)
Substance Abuse Treatment Program-Level Obstacles
Staffing; - No onsite VR counselor; - No staff knowledge about or use of available employment and vocational services; - No staff training in delivery of vocational services; - Lack of understanding about vocational issues; Client--Counselor Interactions; - Poor therapeutic relationship; - Discrepant expectations with respect to vocational goals and needed services; - Agency and counselor attitude about addressing substance abuse disorder before any other issues (e.g., vocational services); Resources; - Inadequate funding for vocational services for clients, staffing, or staff training; - Inadequate networking with other service providers; - Fiscal disincentives brought about by clients' loss of Medicaid or other public assistance as a source of payment for treatment services; Policies; - Lack of commitment to vocational services; - Vocational services not integrated into substance abuse treatment; - Inflexible treatment schedules (e.g., not open on weekends or after 5 p.m. during the week); - Lack of commitment to individualized planning and treatment
Structural Barriers
Employers and Businesses; - Biases against hiring persons in substance abuse treatment, with criminal records, on welfare, of particular gender, with disabilities (coexisting), of a certain ethnicity, or with co-occurring mental disorders; - Unfavorable work environment (see biases above); - Inadequate on-the-job-training; - Inadequate pay scales, promotion policies, or benefit packages; - Lack of supportive services and information; - State-required caregiver background checks and inability to work in various jobs because of background regardless of employer's willingness to hire; Welfare to Work; - Unrealistic expectation regarding client's ability to work now without adequate time to resolve basic problems; Local Labor Market; - Few entry-level jobs at sufficient pay that offer the prospect of advancement and benefits; - Difficulties in matching clients to available jobs; - Lack of, or exclusion from, union membership; - Jobs located too far away for reasonable transportation time; Local Services; - Limited personal or public transportation; - Insufficient safe, affordable housing; - Inadequate regional or local resources (e.g., day care, schools, accessible medical care, libraries); Local Employment Programs and Vocational Services; - Inadequate or out-of-date programs for current labor market needs; - Unsuitable programs and services (e.g., for clients in substance abuse treatment, women); - Insufficient funding for long-term training; - No focus on job retention problems; - Premature job placement when client is not ready; - Waiting lists or other delays in obtaining services; - Insufficient attention to short-term training to accommodate welfare reform mandates; - Insufficient coordination between service systems to identify mutual goals, needed collaborative approaches, and means to eliminate structural programmatic behaviors; Funding; - Work is not a goal for managed care or other insurance and therefore is not funded; Sources: French et al., 1992; Platt, 1995; Wolkstein and Spiller, 1998; Woolis, 1998.