# Appendix I—Field Reviewers

- William J. Allen
- Deputy Director
- Mental Health and Substance Abuse Services
- Department of Community Health
- Lansing, Michigan

- Richard C. Baron, M.A.
- Philadelphia, Pennsylvania

- Adrienne Bitoy-Jackson
- Grants Developer
- Grants Administration
- Chicago Housing Authority
- Chicago, Illinois

- Karen Busha, Ed.M.
- Treatment Director
- Lexington County Residential and Outpatient
- Lexington Richland Alcohol and Drug Abuse Council
- West Columbia, South Carolina

- Susanne Caviness, Ph.D., C.A.P.T., U.S.P.H.S.
- Quality Improvement Advisor
- Office of Pharmacological and Alternative Therapies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Barbara Cimaglio
- Director
- Office of Alcohol and Drug Abuse Programs
- Oregon Department of Human Resources
- Salem, Oregon

- Michael Couty, M.S.
- Director
- Division of Alcohol and Drug Abuse
- Missouri Department of Mental Health
- Jefferson City, Missouri

- John Darin
- President
- The National Association on Drug Abuse Problems, Inc.
- New York, New York

- Lynn F. Duby, M.S.W.
- Director
- Department of Mental Health, Mental Retardation & Substance Abuse Services
- Maine Office of Substance Abuse
- Augusta, Maine

- Laura Faulconer, M.S.W., M.P.A.
- Director, Continuity of Care
- Commonwealth of Virginia
- Northern Virginia Mental Health Institute
- Department of Mental Health, Mental Retardation and Substance Abuse
- Falls Church, Virginia

- Judy Fried, M.A.
- Executive Director
- Women and Children's Program
- Northern Illinois Council on Alcoholism and Substance Abuse
- Round Lake, Illinois

- Nick Gantes, M.P.A.
- Director
- James R. Thompson Center
- Illinois Department of Alcoholism and Substance Abuse
- Chicago, Illinois

- Matthew Gissen
- President
- The Village
- Miami, Florida

- Sharon L. Gottoui, M.A., L.P.C., C.S.A.C.
- Second Genesis
- Bethesda, Maryland

- James Herrera, M.A., L.P.C.C.
- Center on Alcoholism, Substance Abuse and Addictions
- University of New Mexico
- Albuquerque, New Mexico

- James Robert Holden, M.A.
- Program Director
- Partners in Drug Abuse Rehabilitation Counseling
- Washington, D.C.

- Brandon Hunt, Ph.D., N.C.C., C.R.C.
- Assistant Professor
- Counselor Education, Counseling Psychology, and Rehabilitation Services
- The Pennsylvania State University
- University Park, Pennsylvania

- Linda S. Janes, C.C.D.C. III
- Recovery Services Administrator
- Division of Parole and Community Services
- Ohio Department of Rehabilitation and Corrections
- Columbus, Ohio

- Linda Kaplan
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Cathy Keiter, M.A.
- Media, Pennsylvania

- Michael W. Kirby, Jr., Ph.D.
- Chief Executive Officer
- Arapahoe House, Inc.
- Thornton, Colorado

- Russell P. MacPherson, Ph.D., C.A.P., C.A.P.P., C.C.P., D.A.C., D.V.C.
- President
- RPM Addiction Prevention Training
- Deland, Florida

- Marcello Maviglia, M.D.
- Albuquerque, New Mexico

- Dennis Moore, Ed.D.
- Director
- Rehabilitation Research and Training Center on Drugs and Disability
- Wright State University
- Dayton, Ohio

- Ethel Mull
- Vice President
- Treatment Alternatives for Special Clients
- Chicago, Illinois

- Fanny G. Nicholson, C.C.S.W., A.C.S.W., N.C.A.C.I., C.S.A.E.
- Alcohol and Drug Specialist
- Oconaluftee Job Corps
- Cherokee, North Carolina

- Larry D. Raper, M.B.A., M.A., C.A.D.C.
- Director
- Office of Program Compliance and Outcomes Monitoring
- Bureau of Alcohol and Drug Abuse Prevention
- Arkansas Department of Health
- Little Rock, Arkansas

- Steve D. Redfield
- Executive Director
- Strive/Chicago Employment Service
- Chicago, Illinois

- Gwen Rubinstein, M.P.H.
- Deputy Director of National Policy
- Legal Action Center
- Washington, D.C.

- Nancy Siegrist, M.P.A.
- Executive Director
- Lansing Regional Agency
- National Council on Alcoholism
- Lansing, Michigan

- Tom W. Smith
- Health Program Manager
- Office of Consumer Affairs
- Behavioral Health Services Division
- New Mexico Department of Health
- Santa Fe, New Mexico

- Ruth Delores Smith, C.S.W., M.A., C.A.S.A.C.
- Director of Residential Services and Training
- VIP Community Services
- Bronx, New York

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Sushma Taylor, Ph.D.
- Executive Director
- Center Point, Inc.
- San Rafael, California

- Anthony Tusler
- Santa Rosa, California

- Eileen Wolkstein, Ph.D.
- Research Scientist
- School of Education
- Department of Health Studies
- Rehabilitation Counseling Program
- New York University
- New York, New York

- Stephen A. Young
- Director
- Planning and Development
- First Inc.
- Winston Salem, North Carolina

- Dennis Zimmerman
- New York State Office of Alcohol and Substance Abuse Services
- Albany, New York

- Janet Zwick
- Director
- Division of Substance Abuse and Health Promotion
- Iowa Department of Public Health
- Des Moines, Iowa