# Appendix H—Resource Panel

- Candace Baker
- Clinical Affairs Manager
- National Association of Alcohol and Drug Abuse Counselors
- Arlington, Virginia

- Elena Carr
- Substance Abuse Program Coordinator
- Office of the Assistant Secretary for Policy
- Department of Labor
- Washington, D.C.

- Janie Dargan, M.S.N.
- Senior Policy Analyst
- Office of National Drug Control Policy/ E.O.P.
- Washington, D.C.

- Marsha Dubose
- Supervisory Vocational Rehabilitation Specialist
- District Government
- Department of Human Services
- Rehabilitation Services Administration
- Washington, D.C.

- Laura Feig, M.P.P.
- Social Science Analyst
- Division of Children and Youth Policy
- Office of the Assistant Secretary for Planning and Evaluation
- Department of Health and Human Services
- Washington, D.C.

- Sharon L. Gottoui, M.A., L.P.C., C.S.A.C.
- Second Genesis, Inc.
- Bethesda, Maryland

- Jeff A. Hoffman, Ph.D.
- President
- Danya International, Inc.
- Silver Spring, Maryland

- Randy T. Hoover, C.A.S., C.A.C.
- Vocational Counselor
- Second Genesis, Inc.
- Crownsville, Maryland

- Janice Jordan
- Substance Abuse Consultant
- Department of Mental Health, Mental Retardation and Substance Abuse Services
- Richmond, Virginia

- Cathy Keiter, M.A.
- Media, Pennsylvania

- Dennis Moore, Ed.D.
- Director
- Rehabilitation Research and Training Center on Drugs and Disability
- Wright State University
- Dayton, Ohio

- Thomas O'Connell
- Division of Self-Sufficiency
- Administration on Children and Families
- Washington, D.C.

- Gwen Rubinstein, M.P.H.
- Deputy Director of National Policy
- Legal Action Center
- Washington, D.C.

- Daniel Simpson
- HIV/AIDS Coordinator/Alcohol
- Alcoholism and Substance Abuse Program Branch
- Indian Health Service
- Rockville, Maryland

- Barbara J. Spoor, M.P.A.
- Project Director
- American Public Welfare Association
- Washington, D.C.

- Dora Teimouri, M.Ed.
- Rehabilitation Program Specialist
- Rehabilitation Services Administration
- Office of Special Education and Rehabilitative Services
- U.S. Department of Education
- Washington, D.C.