# Appendix G—Sample Individualized Written Rehabilitation Program

This Appendix is a 27Kbyte PDF file. (http://text.nlm.nih.gov/tip/ft-ww/38appxG.PDF)