# Appendix F—Federal Funding Sources

The information about Federal and State funding sources in Figures F-1 and F-2 is intended to illustrate the range of potential Federal funding sources available and should not be regarded as comprehensive. Although every effort was made to ensure that the information was as up-to-date as possible, some information may no longer be current. The information is arranged in the same order as it was presented in the section "Federal and State Funding Sources" in Chapter 6.

Each of the funding sources listed in Figure F-1 has its own eligibility and reporting requirements and funding cycle. Some programs are competitive, whereas others award funding by formula. Although substance abuse treatment programs may not be able to compete directly for some of these funds, they may be able to subcontract with a funded agency. They can also have a crucial advocacy role in deciding funding priorities.

The following acronyms are used in Figure F-1.

- CHIP = Child Health Insurance Plan
- DHHS = Department of Health and Human Services
- DOE = Department of Education
- DOJ = Department of Justice
- DOL = Department of Labor
- DOT = Department of Transportation
- EZ/EC = Enterprise Zone/Empowerment Community
- HCFA = Health Care Financing Administration
- JTPA = Job Training Partnership Act
- SAPT Block Grant = Substance Abuse Prevention and Treatment Block Grant
- SSA = Single State Agency (i.e., the primary State agency responsible for publicly funded substance abuse treatment services)
- TANF = Temporary Assistance to Needy Families
- USDA = United States Department of Agriculture
- VR = Vocational Rehabilitation