# Appendix E—State Employment Agencies

- ALABAMA
- Alabama State Employment Service
- 649 Monroe St, Room 266
- Montgomery, AL 36131
- Phone: (334) 242-8003; Fax: (334) 242-8012
- Web site: http://www.dir.state.al.us/es/

- ALASKA
- Alaska Career Information System
- Alaska Department of Education
- 801 West 10th Street, Suite 20
- Juneau, AK 99801-1894
- Phone: (907) 465-2980; Fax: (907) 465-2982
- Web site: www.jobs.state.ak.us

- ARIZONA
- Employment and Rehabilitation Services
- Arizona Department of Economic Security
- 1831 W. Jefferson
- Phoenix, AZ 85007
- Phone: (602) 542-4941 or (602) 542-5216
- Web site: www.azrsa.org/frames.html

- ARKANSAS
- Arkansas Employment Security Department
- #2 Capital Mall, Room 506
- ESD Building
- Little Rock, AR 72201
- Phone: (501) 682-2121; Fax: (501) 682-2273
- Web site: www.state.ar.us/esd

- CALIFORNIA
- The California State Job Training Coordinating Council
- 800 Capitol Mall, MIC 67
- Sacramento, CA 95814
- Phone: (916) 654-6836; Fax: (916) 654-8987
- Web site: www.sjtcc.cahwnet.gov

- COLORADO
- Colorado Department of Labor and Employment
- Attn: Public Relations
- 1515 Arapahoe Street, Tower 2, Suite 500
- Denver, CO 80202-2117
- Phone: (303) 620-4718
- Web site: cdle.state.co.us

- CONNECTICUT
- Employment Training/Connecticut Works
- Connecticut Department of Labor
- 200 Folly Brook Boulevard
- Wethersfield, CT 06109
- Phone: (888) 289-6757 [(888) CTWORKS]
- Web site: www.ctdol.state.ct.us

- DELAWARE
- Delaware Department of Labor
- Division of Employment and Training
- First Floor4425 North Market StreetWilmington, DE 19806
- Web site: /www.vcnet.net

- DISTRICT OF COLUMBIA
- Department of Employment Services
- Training, Referral and Assessment Office
- 500 C Street, NW, Room 300Washington, DC 20001
- Phone: (202) 724-2300
- Web site: http://does.ci.washington.dc.us/seeker.html

- FLORIDA
- Florida Department of Labor & Employment Security
- Division of Vocational Rehabilitation - Bldg A
- 2002 Old Augustine Road
- Tallahassee, FL 32399
- Phone: (850) 488-6210 or (850) 488-4398 (general information)
- Web site: www.state.fl.us/dles/

- GEORGIA
- Georgia Department of Labor
- Suite 642
- 148 International Boulevard N.E.
- Atlanta, GA 30303-1751
- Phone: (404) 656-3032
- Web site: www.dol.state.ga.us

- HAWAII
- Department of Labor and Industrial Relations Workforce Development Division
- 830 Punchbowl Street
- Honolulu, HI 96813
- Phone: (808) 586-8842; Fax: (808) 586-9099
- Web site: www.dlir.state.hi.us/wdd or
- www.aloha.net/~edpso/annual.html

- IDAHO
- Idaho Department of Labor
- 317 Main Street
- Boise, ID 83735-0600
- Phone: (208) 334-6252; Fax: (208) 334-6300
- Web site: www.labor.state.id.us

- ILLINOIS
- Illinois Department of Employment Security
- Field Operations
- 401 S. State Street, 7th North
- Chicago, IL 60605
- Phone: (312) 793-2713; in Springfield: (217) 785-5069
- Web site: www.ides.state.il.us

- INDIANA
- Department of Workforce Development
- 10 N. Senate Avenue
- Indianopolis, IN 46204
- Phone: (317) 232-7670; Fax: (319) 233-4793
- Web site: www.dwd.state.in.us

- IOWA
- Iowa Workforce Development
- 1000 East Grand Avenue
- Des Moines, IA 50319-0209
- Phone: (515) 281-5387, 800-JOB-IOWA
- Web site: www.state.ia.us/iwd

- KANSAS
- Kansas Department of Human Resources
- 1430 SW Topeka Boulevard
- Topeka, KS 66612-1897
- Phone: (785) 296-1715; Fax: (785) 296-1984
- Web site: http://www.hr.state.ks.us

- KENTUCKY
- Workforce Development Cabinet
- Department for Employment Services
- 275 East Main StreetFrankfort, KY 40621Phone: (502) 564-5331
- Web site: www.state.ky.us/agencies/wforce/des/des.htm

- LOUISIANA
- Louisiana Department of Labor
- 735 St. Charles Avenue
- New Orleans, LA 70130-3713
- Phone: (504) 568-7111; Fax: (504) 568-7195
- Web site: www.ldol.state.la.us/homepage.htm

- MAINE
- Department of Labor
- Job Service
- Bureau of Employment Services
- 55 State House Station
- Augusta, ME 04333-0055
- Phone: (207) 624-6390; Fax: (207) 624-6499
- Web site: /www.state.me.us/labor/jsd/jobserv.htm

- MARYLAND
- Maryland Job Service
- Division of Employment and Training
- Phone: (800) 765-8692
- Web site: /www.dllr.state.md.us/employment

- MASSACHUSETTS
- Massachusetts Division of Employment and Training
- 19 Staniford Street
- Boston, MA 02114
- Phone: (617) 727-6560
- Web site: www.masscareers.state.ma.us

- MICHIGAN
- Michigan Department of Career Development
- [formerly Michigan Jobs Commission]
- 201 N. Washington Square
- Victor Office Center, 4th Floor
- Lansing, MI 48913
- Phone: (517) 373-9808
- Web site: www.state.mi.us/mjc/ceo
- E-mail: Customer-Assistance@state.mi.us

- MINNESOTA
- Minnesota Department of Economic Security
- 390 N. Robert Street
- St. Paul, MN 55101
- Phone: (888) 438-5627
- Web site: www.des.state.mn.us

- MISSISSIPPI
- Mississippi Employment Security Commission
- P.O. Box 1699
- Jackson, MS 39215-1699
- Phone: (601) 354-8711; Fax: (601) 961-7405
- Web site: www.mesc.state.ms.us/index.html

- MISSOURI
- Workforce Development Transition Team
- P.O. Box 1928
- Jefferson City, MO 65102-1928
- Phone: (573) 751-7039; Fax: (573) 751-0147
- Web site: wfd-info.works.state.mo.us

- MONTANA
- Montana Department of Labor and Industry
- Job Service Division
- Web site: jsd.dli.state.mt.us

- NEBRASKA
- Nebraska Department of Labor
- 550 South 16th Street
- Lincoln, NE 68509-4600
- Phone: (402) 471-2600; Fax: (402) 471-9867
- Web site: www.dol.state.ne.us/index.htm

- NEVADA
- Nevada Department of Employment, Training and Rehabilitation
- Information Development and Processing Division
- Research & Analysis Bureau
- 500 E. Third Street
- Carson City, NV 89713
- Phone: (702) 687-4550
- Web site: www.state.nv.us/detr/detr.html

- NEW HAMPSHIRE
- New Hampshire Employment Security
- Web site: www.nhworks.state.nh.us/

- NEW JERSEY
- New Jersey State Employment & Training Commission
- P.O. Box 940
- Trenton, NJ 08625-0940
- Web site: www.wnjpin.state.nj.us/OneStopCareerCenter/SETC

- NEW MEXICO
- New Mexico Department of Labor
- Employment Security Division
- 401 Broadway NE
- Albuquerque, NM 87102
- Web site: www3.state.nm.us/dol/dol_jobs.html

- NEW YORK
- Workforce Development and Training
- New York State Department of Labor
- State Campus, Building 12
- Albany, NY 12240
- Phone: (518) 457-0380; Fax: (518) 457-9526
- Web site: http://www.wdsny.org

- NORTH CAROLINA
- North Carolina Division of Employment & Training
- 441 N. Harrington Street
- Raleigh, NC 27603
- Phone: (919) 733-6383
- Web site: www.jtpa.state.nc.us

- NORTH DAKOTA
- Job Service North Dakota
- P.O. Box 5507
- Bismarck, ND 58506-5507
- Phone: (800) 732-9787 or (701) 328-2868;
- Fax: (701) 328-4193
- Web site: www.state.nd.us/jsnd

- OHIO
- Ohio Bureau of Employment Services
- 145 S. Front Street
- Columbus, OH 43215
- Web site: www.state.oh.us/obes
- E-mail: wwwobes@ohio.gov

- OKLAHOMA
- Oklahoma Employment Security Commission
- Will Rogers Office Building
- 2401 North Lincoln Blvd.
- P. O. Box 52003
- Oklahoma City, OK 73152-2003
- Phone: (405) 557-0200
- Web site: /www.oesc.state.ok.us

- OREGON
- Oregon Employment Department
- 875 Union Street, N.E.
- Salem, OR 97311
- Web site: www.emp.state.or.us

- PENNSYLVANIA
- Career Development Marketplace Unit
- c/o Department of Labor and Industry
- 412 Labor and Industry Building
- 7th & Forster Streets
- Harrisburg, PA 17120
- Web site: www.li.state.pa.us/paworks/paworks.html

- RHODE ISLAND
- Rhode Island Department of Labor and Training
- 101 Friendship Street
- Providence, RI 02903
- Phone: (401) 222-3625
- Web site: www.dlt.state.ri.us

- SOUTH CAROLINA
- South Carolina Employment Security Commission
- 1550 Gadsden Street
- Columbia, SC 29202
- Web site: www.sces.org

- SOUTH DAKOTA
- South Dakota Department of Labor
- 700 Governors Drive
- Pierre, SD 57501-2291
- Phone: (605) 773-3101; Fax: (605) 773-4211
- Web site: www.state.sd.us/dol/dol.htm

- TENNESSEE
- Tennessee Department of Employment Security
- Davy Crockett Tower - 11th Floor
- 500 James Robertson Parkway
- Nashville, TN 37245-1200
- Phone: (615) 741-213
- Web site: www.state.tn.us/empsec

- TEXAS
- Texas Workforce Commission
- 101 E. 15th Street
- Austin, TX 78778-8001
- Web site: www.twc.state.tx.us

- UTAH
- Utah Department of Workforce Services
- P.O. Box 45249
- Salt Lake City, UT 84145-0249
- Phone: (801) 526-WORK (9675);
- Fax: (801) 536-7420
- Web site: www.dws.state.ut.us

- VERMONT
- Vermont Department of Employment and Training
- 5 Green Mountain Drive
- P.O. Box 488
- Montpelier, VT 05601-0488
- Phone: (802) 828-4000; Fax: (802) 828-4022
- Web site: www.det.state.vt.us

- VIRGINIA
- Virginia Employment Commission
- 5520 Cherokee Avenue, Suite 100
- Alexandria, VA 22312- 2319
- Phone: (703) 813-1300; Fax: (703) 813-1380
- Web site: www.vec.state.va.us

- WASHINGTON
- Washington State Employment Security Department
- Commissioner's Office
- 212 Maple Park Drive
- P.O. Box 9046
- Olympia, WA 98507-9046
- Phone: (360) 902-9301; Fax: (360) 902-9383
- Web site: www.wa.gov/esd/esdhome.html

- WEST VIRGINIA
- West Virginia Bureau of Employment Programs
- 112 California Avenue
- Charleston, WV 25305-0112
- Phone: (304) 558-2630
- Web site: www.state.wv.us/bep

- WISCONSIN
- Wisconsin Department of Workforce Development
- 201 E. Washington Avenue
- P.O. Box 7946
- Madison, WI 53707-7946
- Web site: www.dwd.state.wi.us/default.htm

- WYOMING
- Wyoming Department of Employment
- 122 West 25th Street
- Cheyenne, WY 82002
- Phone: (307) 777-7672
- Web site: wydoe.state.wy.us