# Appendix D—Addiction Severity Index

This Appendix is a 48Kbyte PDF file