# Appendix C—Published Resource Materials

Bolles, R.N. The 1999 What Color Is Your Parachute: A Practical Manual for Job-Hunters and Career-Changers. Berkeley, CA: Ten Speed Press, 1998.

Brown, C.; McDaniel, R.; Couch, R.; and McClenahan, M. Vocational Evaluation Systems and Software: A Consumer's Guide. Menomonie, WI: University of Wisconsin-Stout, 1994.

Farley, R.C. Developing and Enhancing Interview Skills: A Supplemental Manual for the Interviewing Skills Training Workshop. Hot Springs, AR: Arkansas Research and Training Center on Vocational Rehabilitation, 1983.

Hinman, S.; Means, B.; Parkerson, S.; and Odendahl, B. Manual for the Job-Seeking Skills Assessment. Hot Springs, AR: Arkansas Research and Training Center on Vocational Rehabilitation, 1988.

Holland, J.L. Self-Directed Search (SDS) Form R, 4th ed. Tampa, FL: Psychological Assessment Resources, Inc. 1997.

Kapes, J.T.; Mastie, M.M.; and Whitfield, E.A. Counselor's Guide to Career Assessment Instruments, 3rd ed. Alexandria, VA: American Counseling Association, 1994.

Matrix Research Institute. (many publications) 6008 Wayne Avenue, Philadelphia, PA 19144. Tel: (215) 438-8200; Fax: (215) 438-8337; TDD: (215) 438-1506; e-mail: WorkMRI@aol.com; Web site: www.matrixresearch.org/pub2vocrehab.html

National Institute on Drug Abuse. Assessing Client Needs Using the ASI: A Handbook for Program Administrators. Washington, DC: U.S. Government Printing Office, 1995.

Power, P.W. A Guide to Vocational Assessment, 2nd ed. Austin, TX: PRO-ED, 1991.

U.S. Department of Labor. Manual for the General Aptitude Test Battery, Section III: Development. Washington, DC: U.S. Government Printing Office, 1970.

U.S. Department of Labor. Guide for Occupational Exploration. Washington, DC: U.S. Government Printing Office, 1979.

U.S. Department of Labor. Instructions for Administering and Using the Interest Check List. Washington, DC: U.S. Government Printing Office, 1979.

U.S. Department of Labor. Manual for the USES Interest Inventory. Minneapolis, MN: Intran Corporation, 1982.

## Internet Sites

- America's Career InfoNet:
- http://www.acinet.org/acinet/
- America's Labor Market Information System:
- http://dwsa.state.ut.us/almis/
- Federal Transit Administration:
- http://www.fta.dot.gov/wtw
- Housing and Urban Development:
- http://www.hud.gov/wlfrefrm.html
- Matrix Research Institute:
- http://www.matrixresearch.org/pub2vocrehab.html
- National Clearinghouse of Rehabilitation Training Materials:
- www.nchrtm.okstate.edu
- National Occupational Information Coordinating Committee:
- http://www.noicc.gov/
- U.S. Department of Labor:
- http://www.dol.gov/
- U.S. Department of Labor, Welfare-to-Work:
- http://wtw.doleta.gov
- Welfare Information Network :
- www.welfareinfo.org
- Welfare to Work Partnership:
- www.welfaretowork.org
- Workforce Investment Act of 1998 information:
- http://usworkforce.org

## Software

- Open Options for Windows.
- Order from Career Planning Specialists Software, Inc., 362 S. Harvey St., Plymouth, MI 48170. Voice: (313) 459-7348. Fax: (313) 459-9833.
- Center for Substance Abuse Prevention (CSAP)
- Prevention Works! Software.