# Appendix B --Resources: Tools and Instruments

Appendix B --Resources: Tools and Instruments

Title: | Addiction Severity Index Package
Purpose: | To evaluate client functioning in seven life areas: employment, medical, alcohol use, drug use, legal, family/social, and psychiatric; often used as an outcome measure before and after treatment.
Target Population: | Substance abuse disorder and mental health clients (adult version)
Administration: | Both clinician-administered and client self-administered forms; paper and pencil and software versions are available.
Test/Scoring Time: | Approximately 60 minutes
Price: | $63 (kit includes 240-page manual and 2-hour VHS video)
| Some ASI materials may be distributed without cost. See Appendix D for one version of this instrument.
Available From: | National Technical Information Service (NTIS) Order Desk
| 5285 Port Royal Road
| Springfield, VA 22161
| (888) 584-8332 Fax: (703) 605-6900
| www.ntis.gov.
E-mail: info@ntis.fedworld.gov
| Also available from: Delta Metrics
| 2005 Market Street, Suite 1120
| Philadelphia PA 19103
| (215) 665-2880, (215) 665-2892
| For SOFTWARE versions of ASI (Adult and Adolescent versions, and Treatment Plans), contact:
| Accurate Assessments
| 183 Harney, Ste. 101
| Omaha, NE 68102
| (800) 324-7960
Title: | Adult Basic Learning Examination (ABLE)
Authors: | Bjorn Karlsen, Eric F. Gardner
Purpose: | Measures adult learning in a variety of adult education programs, including Tech Prep programs, GED programs, and adult literacy programs.
Target Population: | Adults
Administration: | Designed for classroom use. Consists of 3 levels: level 1 for adults who have completed 1-4 years of formal education; level 2 for adults with 5-8 years of schooling; level 3 for adults with at least 8 years of schooling and who may or may not have graduated from high school. A Spanish version of level 2 is available as well. Related products are available.
Test/Scoring Time: | Untimed; each level averages 2 hours, 40 minutes. ABLE Screening Battery averages about 1 hour.
Price: | $55.75 (kit includes level 1, 2, 3 test booklets, directions for administering, group record, hand-scorable answer sheet, READY SCORE answer sheet, and Selectable READY SCORE answer sheet)
Available From: | The Psychological Corporation
| 555 Academic Court
| San Antonio, TX 78204
| Attn: Clinical Sales
| (800) 211-8378 Fax: (800) 232-1223
| www.hbem.com; (http://www.hbem.com;/) www.psychcorp.com
Title: | Career Attitudes and Strategies™ (CASI): An Inventory for Understanding Adult Careers (1994)
Authors: | John L. Holland, Ph.D.; Gary D. Gottfredson, Ph.D.
Purpose: | Assesses attitudes related to career, identifies career problems and obstacles in employed and unemployed adults.
Target Population: | Adults
Administration: | Self-administered; individual
Test/Scoring Time: | 35 minutes
Price: | $75 (introductory kit includes manual, 25 inventory booklets, 25 hand-scorable answer sheets, and 25 interpretive summary booklets)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Career Thoughts Inventory™ (CTI) (1996)
Authors: | James P. Sampson, Jr., Ph.D.; Gary W. Peterson, Ph.D.; Janet G. Lenz, Ph.D.; Robert C. Reardon, Ph.D.; Denise E. Saunders, M.S.
Purpose: | Assists in career problemsolving and decisionmaking; assesses for and alters negative career thinking.
Target Population: | Adults, college students, and high school students
Administration: | Individual or group
Test/Scoring Time: | 7-15 minutes
Price: | $89 (kit includes CTI professional manual, 5 workbooks, 25 test booklets)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Crawford Small Parts Dexterity Test (CSPDT)
Author: | John Crawford
Purpose: | Tests manual dexterity.
Administration: | The two-part, pegboard-type test uses a wooden board with separate wells for pins, collars, and screws.
Test/Scoring Time: | 3 minutes for part 1; 5 minutes for part 2.
Price: | Kit: $564.10 (Canadian)
| Manual: $22.44 (Canadian)
Available From: | M.D. Angus & Associates Ltd.
| 2639 Kingsway Avenue, 2nd floor
| Port Coquitlam, BC V3C 1T5
| Canada
| (604) 464-7919 Fax: (604) 941-1705
| www.psychtest.com
Title: | Geist Picture Interest Inventory
Author: | Harold Geist, Ph.D.
Purpose: | Identifies vocational and avocational interests, especially with culturally different and educationally deprived persons.
Target Population: | Grade 8 through adult
Administration: | Individually or to groups
Test/Scoring Time: | Scoring takes a few minutes.
Price: | $78.50 (kit includes test booklets for males and females, and manual)
Available From: | Western Psychological Services
| 12031 Wilshire Blvd.
| Los Angeles, CA 90025
| (800) 648-8857 Fax: (310) 478-7838
Title: | General Aptitude Test Battery (GATB)
Purpose: | Measures 9 aptitudes with 12 separate tests. The last five tests involve pegboards.
Target Population: | Grade 9 to adult
Administration: | Comprises two test booklets with four separately sold answer sheets and two pegboards (small parts and gross motor). May be administered to small groups, except for the small parts and gross motor test. The pegboards are expensive and relatively difficult to administer. Their use may be warranted if residual neurological impairment is suspected (e.g., in recovering alcoholics).
Test/Scoring Time: | 1 hour
Price: | Test booklets: $71.50 each
| Prices of answer sheets and pegboards may be viewed in online catalog at www.psychtest.com/curr02
Available From: | M.D. Angus & Associates Ltd.
| 2639 Kingsway Avenue, 2nd floor
| Port Coquitlam, BC V3C 1T5
| Canada
| (604) 464-7919 Fax: (604) 941-1705
| www.psychtest.com
Title: | Kuder Occupational Interest Survey (KOIS)
Author: | Frederic Kuder
Purpose: | Assesses interest of students and adults in areas related to higher education and occupations.
Target Population: | Grade 10 through adult
Price: | $135.10 (package includes 20 books with items and response section, complete scoring, individual narrative reports, counselor's narrative reports, instructions; manual sold separately)
Available From: | CTB/McGraw-Hill
| 20 Ryan Ranch Road
| Monterey, CA 93940
| (800) 538-9547 Fax: (800) 282-0266
Title: | System 2000 (formerly Microcomputer Evaluation Screening and
Assessment [MESA] System)
Purpose: | A modular software system for IBM-compatible personal computers, including a career planner, census database, computerized assessment, competencies database, dictionary of occupational titles (DOT), and more. Modules can be purchased separately.
Price: | Varies by module (e.g., system manager, $300; computerized assessment, $3,875; DOT database, $1,015)
Available From: | Valpar International Corporation
| P.O. Box 5767
| Tucson, AZ 85703-5767
| (800) 528-7070 Fax: (520) 292-9755
| www.valparint.com
Title: | Minnesota Clerical Test (MCT) (1979)
Authors: | Dorothy Andrew, et al.
Purpose: | Measures aptitude for office work such as bookkeeping, filing.
Price: | Examination kit: $41.67 (Canadian)
| Booklets (25): $102.56 (Canadian)
| Manual: $35.26 (Canadian)
| Scoring key: $32.05 (Canadian)
Available From: | M.D. Angus & Associates Ltd.
| 2639 Kingsway Avenue, 2nd floor
| Port Coquitlam, BC V3C 1T5
| Canada
| (604) 464-7919 Fax: (604) 941-1705
| www.psychtest.com
Title: | My Vocational Situation (MVS)
Authors: | John L. Holland, Ph.D.; Denise Daiger; Paul G. Power
Purpose: | Helps determine lack of vocational identity, lack of information or training, or emotional or personal barriers.
Target Population: | Adults
Administration: | Self-administered
Test/Scoring Time: | Less than 10 minutes; can be tabulated "at a glance"
Price: | $25 (kit includes manual and 50 questionnaires)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Peabody Picture Vocabulary Test (PPVT-III)
Purpose: | Measures listening comprehension for spoken words in standard English, provides a screening test of verbal ability.
Target Population: | 2.5-90+ years
Administration: | Individually administered
Test/Scoring Time: | 11-12 minutes
Price: | $149.50 for basic kit; other related products available at various prices.
Available From: | AGS/American Guidance Service
| 4201 Woodland Road
| Circle Pines, MN 55014-1796
| (800) 328-2560 or (612) 786-4343 Fax: (800) 471-8457 or (612) 786-9077
| E-mail: agsmail@agsnet.com
Title: | Psychological Screening Inventory
Author: | Richard I. Lanyon, Ph.D.
Purpose: | Provides brief, nonthreatening mental health screening. Identifies people who might benefit from more extensive examination.
Target Population: | Adults and adolescents
Administration: | Individual or group
Test/Scoring Time: | 15 minutes
Price: | $49 (includes manual, question and answer sheets, scoring templates, and profile sheets)
Available From: | Sigma Assessment Systems, Inc.
| 511 Fort Street, Suite 435
| P.O. Box 610984
| Port Huron, MI 48061-0984
| (800) 265-1285 Fax: (800) 381-9411
Title: | Reading-Free Vocational Interest Inventory (R-FVII)
Author: | Ralph L. Becker, Ph.D.
Purpose: | Measures vocational interests, likes, and dislikes of special populations.
Target Population: | Learning disabled, mentally retarded, and disadvantaged individuals ages 13 and older
Administration: | Individual or group
Test/Scoring Time: | 20 minutes
Price: | $84 (introductory kit includes manual, occupational title lists, and 20 test booklets)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Revised Beta Examination (Beta II)
Authors: | C.E. Kellogg, N.W. Morton
Price: | $153.85 (Canadian) (kit includes booklets, key, manual)
Available From: | M.D. Angus & Associates Ltd.
| 2639 Kingsway Avenue, 2nd floor
| Port Coquitlam, BC V3C 1T5
| Canada
| (604) 464-7919 Fax: (604) 941-1705
| www.psychtest.com
Title: | Self-Directed Search® (SDS®) (several versions available)
Author: | John L. Holland, Ph.D.
Purpose: | Assesses vocational interests and long-term career planning.
Target Population: | Individuals on the career-development track
Administration: | Self-administered; individual or group
Test/Scoring Time: | 15-25 minutes
Price: | $133 (for Form CP: Career Planning) (introductory kit includes professional user's guide, technical manual, 25 form CP assessment booklets, 25 career options finders, and 25 exploring career options booklets)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Slosson Intelligence Test-Revised (SIT-R)
Authors: | Richard L. Slosson, Ph.D. Revised by Charles L. Nicholson, Ph.D., Terry L. Hibpshman, Ph.D.
Purpose: | Provides a quick, reliable measure of intelligence to determine if further, in-depth evaluation is needed. Slosson Full-Range Intelligence Test (S-FRIT) (1993) is also available from source listed below ($119/kit).
Target Population: | Ages 4 years and older
Administration: | Individual
Test/Scoring Time: | 10-30 minutes
Price: | $91 (introductory kit includes manual, norm tables, and 50 score sheets)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Strong Interest Inventory
Purpose: | Measures interest in a broad range of occupations, work activities, leisure activities, and school subjects.
Target Population: | Clients interested in career development or job change, as well as students exploring careers
Administration: | Licensed therapist or other professional trained in testing administration
Test/Scoring Time: | 30-40 minutes (317 items)
Price: | Several versions available ranging from $69 to $135. Applications and technical guide: $57.75
Available From: | Consulting Psychologists Press, Inc. (CPP)
| 3803 East Bayshore Road
| Palo Alto, CA 94303
| (800) 624-1765 Fax: (650) 969-8608
Title: | Tennessee Self-Concept Scale (TSCS:2)
Authors: | William H. Fitts, Ph.D.; W.L. Warren, Ph.D.
Purpose: | Measures self-concept in adolescents, adults, and children.
Target Population: | Adolescents, adults, children
Administration: | Individual or group
Test/Scoring Time: | 10-20 minutes
Price: | $130 (kit includes manual, answer forms, and 4 prepaid mail-in answer sheets)
Available From: | Western Psychological Services
| 12031 Wilshire Boulevard
| Los Angeles, CA 90025
| (800) 648-8857 Fax: (310) 478-7838
Title: | Vocational Preference Inventory™ (VPI) (1985)
Author: | John L. Holland, Ph.D.
Purpose: | Assesses career interests through a brief personality/interest inventory based on the RIASEC personality theory.
Target Population: | Adults and older adolescents
Administration: | Self-administered
Test/Scoring Time: | 15-30 minutes
Price: | $44 (introductory kit includes manual and 25 test booklet/answer sheet/profile combinations)
Available From: | Western Psychological Services
| 12031 Wilshire Boulevard
| Los Angeles, CA 90025
| (800) 648-8857 Fax: (310) 478-7838
Title: | Wechsler Adult Intelligence Scale (WAIS-III)
Author: | David Wechsler
Purpose: | The most widely used ability assessment instrument; results reflect age and abilities of today's population.
Target Population: | Ages 16-89
Administration: | Individual
Price: | $625 (complete set includes administration and norms manual, technical manual, stimulus booklet, record forms, response booklets, object assembly subtest, block design subtest, picture arrangement subtest, and scoring templates)
Available From: | The Psychological Corporation
| 555 Academic Court
| San Antonio, TX 78204
| Attn: Clinical Sales
| (800) 211-8378 Fax: (800) 232-1223
| www: hbem.com; www.psychcorp.com
Title: | Wide Range Achievement Test 3 (WRAT3)
Author: | Gary S. Wilkinson, Ph.D.
Purpose: | Measures development of reading, spelling, and arithmetic skills. New standardization of this widely used test yields all new grade ratings.
Target Population: | Ages 5-75
Administration: | Individual or group
Test/Scoring Time: | 15-30 minutes
Price: | $142 (introductory kit includes manual, 25 blue test forms, 25 tan test forms, 25 profile/analysis forms, plastic word list cards, and soft canvas carrying case)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Wide Range Interest-Opinion Test (WRIOT) (1979)
Author: | Joseph F. Jastak, Ph.D.; Sarah Jastak, Ph.D.
Purpose: | Culturally and sexually unbiased pictorial interest test for vocational career planning and counseling. No reading or language understanding required.
Target Population: | Ages 5 through adult
Administration: | Individually or in groups (individual administration is necessary for those too limited by age, mental ability, or physical limitations to complete the answer sheet). Self-loading IBM scoring package available.
Price: | $150 (starter set includes manual profile/report, picture book, answer sheets, scoring stencils, attaché case)
Available From: | Wide Range, Inc.
| 15 Ashley Place, Suite 1A
| Wilmington, DE 19804-1314
| (800) 221-9728 Fax: (302) 652-1644
Title: | Wonderlic Basic Skills Test™ (WBST)
Purpose: | Measures job-related math and language skills to identify basic skill levels of job applicants and employees.
Target Population: | Teenagers and adults
Administration: | Individual
Test/Scoring Time: | 20 minutes
Price: | $115 (introductory kit includes user's manual, 25 verbal tests, 25 quantitative tests, and scoring diskette with 25 uses for each test)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com
Title: | Work Potential Profile (WPP)
Purpose: | Identifies current characteristics and dispositions of older adolescents and adults seeking employment. Provides a criterion-referenced profile for the initial assessment of long-term unemployed persons and persons who have difficulty finding employment.
Target Population: | Adolescents and adults
Administration: | Individual or group; self-administered
Test/Scoring Time: | Untimed
Price: | $150 (introductory kit includes manual, 10 WPP questionnaires, 10 WPP answer sheets, 10 WPP group summary forms, 10 individual summary forms, and 8 score keys)
Available From: | Psychological Assessment Resources, Inc.
| P.O. Box 998
| Odessa, FL 33556
| (800) 331-TEST
| www.parinc.com