# Consensus Panel

Chair
- Nancy K. Young, M.S.W., Ph.D.
- Director
- Children and Family Futures
- Irvine, California

Workgroup Leaders
- Leslie Chernen, Ph.D.
- Project Director
- Brown University
- Rhode Island Public Health Foundation
- Providence, Rhode Island
- Sidney Gardner, M.P.A.
- Director
- California State University - Fullerton
- Center for Collaboration for Children
- Irvine, California
- Margaret K. Glenn, Ed.D., C.R.C.
- Assistant Professor
- School of Allied Health Professions Counseling
- Virginia Commonwealth University
- Richmond, Virginia
- Gale Saler, M.Ed., C.R.C.-M.A.C., C.P.C.
- Deputy Executive Director
- Second Genesis
- Bethesda, Maryland
- Terry Soo-Hoo, Ph.D.
- Clinic Director
- Assistant Professor
- Counseling Psychology Department
- University of San Francisco
- San Francisco, California
- Diana D. Woolis, Ed.D.
- Senior Research Associate
- Program Demonstration
- National Center on Addiction and Substance Abuse at Columbia University
- New York, New York

Panelists
- Judith Arroyo, Ph.D.
- Project Director
- COMBINE
- University of New Mexico Center on Alcoholism, Substance Abuse, and Addictions
- Albuquerque, New Mexico
- Yvonne F. Bushyhead, J.D.
- Executive Director
- Vocational Opportunities of Cherokee
- Cherokee, North Carolina
- Alfanzo K. Dorsey, M.S.W.
- State Treatment Director
- Social Rehabilitation Services
- Kansas State Alcohol and Drug Abuse Services
- Topeka, Kansas
- Eduardo Duran, Ph.D.
- Clinical Supervisor
- Behavioral Health
- Rehobeth Hospital
- Gallup, New Mexico
- Paul Ingram, M.S.W.
- President/CEO
- Administrative Branch
- PBA, Inc. - The Second Step
- Pittsburgh, Pennsylvania
- Tim Janikowski, Ph.D., C.R.C.
- Associate Professor
- Rehabilitation Counselor Training Program
- Rehabilitation Institute
- Southern Illinois University
- Carbondale, Illinois
- Gloster Mahon, M.S.
- Project Manager
- Illinois Jobs Advantage Project
- Chicago, Illinois
- Angela G. Rojas-Dedenbach, M.A.
- Director
- Michigan Jobs Commission Rehabilitation Services
- Lansing, Michigan
- Alex Trujillo, M.S.
- Clinical Counselor
- Counseling and Therapy Services
- University of New Mexico Student Health Center
- Albuquerque, New Mexico