# Editorial Advisory Board

- Karen Allen, Ph.D., R.N., C.A.R.N.
- Professor and Chair
- Department of Nursing
- Andrews University
- Berrien Springs, Michigan

- Richard L. Brown, M.D., M.P.H.
- Associate Professor
- Department of Family Medicine
- University of Wisconsin School of Medicine
- Madison, Wisconsin

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical/Professional Affairs
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Linda S. Foley, M.A.
- Former Director
- Project for Addiction Counselor Training
- National Association of State Alcohol and Drug Abuse Directors
- Director
- Treatment Improvement Exchange Project
- Washington, D.C.

- Wayde A. Glover, M.I.S., N.C.A.C. II
- Director
- Commonwealth Addictions Consultants and Trainers
- Richmond, Virginia

- Pedro J. Greer, M.D.
- Assistant Dean for Homeless Education
- University of Miami School of Medicine
- Miami, Florida

- Thomas W. Hester, M.D.
- Former State Director
- Substance Abuse Services
- Division of Mental Health, Mental Retardation and Substance Abuse
- Georgia Department of Human Resources
- Atlanta, Georgia

- James G. (Gil) Hill, Ph.D.
- Director
- Office of Rural Health and Substance Abuse
- American Psychological Association
- Washington, D.C.

- Douglas B. Kamerow, M.D., M.P.H.
- Director
- Center for Practice and Technology Assessment
- Agency for Healthcare Research and Quality
- Rockville, Maryland

- Stephen W. Long
- Executive Director
- Office of Policy Analysis
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, Maryland

- Richard A. Rawson, Ph.D.
- Executive Director
- Matrix Center and Matrix Institute on Addiction
- Deputy Director, UCLA Addiction Medicine Services
- Los Angeles, California

- Ellen A. Renz, Ph.D.
- Former Vice President of Clinical Systems
- MEDCO Behavioral Care Corporation
- Kamuela, Hawaii

- Richard K. Ries, M.D.
- Director and Associate Professor
- Outpatient Mental Health Services and Dual Disorder Programs
- Harborview Medical Center
- Seattle, Washington

- Sidney H. Schnoll, M.D., Ph.D.
- Chairman
- Division of Substance Abuse Medicine
- Medical College of Virginia
- Richmond, Virginia