# Consensus Panel

Chair
- Judy Howard, M.D.
- Professor of Pediatrics
- Developmental Studies Program
- Department of Pediatrics
- School of Medicine
- University of California at Los Angeles
- Los Angeles, California

Workgroup Leaders
- Lynn Dorman, Ph.D., J.D.
- Brattleboro, Vermont
- David Duncan, Dr.P.H., C.A.S.
- Associate Professor
- Center for Alcohol and Addiction Studies
- Brown University
- Providence, Rhode Island
- Jerry P. Flanzer, D.S.W., L.C.S.W., C.A.C.
- Director
- Recovery and Family Treatment, Inc.
- Alexandria, Virginia
- Marie Littlejohn, M.S.W., C.S.W.
- Director of Social Work
- Maternity Infant Care
- Medical and Health Research Association
- New York, New York
- Joan E. Massaquoi, M.S.W., L.C.S.W., B.C.D.
- Chicago, Illinois
- Thomas J. McMahon, Ph.D.
- Assistant Professor of Psychology
- Substance Abuse Center
- Yale School of Medicine
- New Haven, Connecticut

Panelists
- Sarah A. Addlesberger
- Program Coordinator
- Castle Medical Center
- Ocean View, Hawaii
- Christian A. Akiwowo, Ph.D.
- President/Chief Executive Officer
- Alajobi Rehabilitative Services
- Olympia Fields, Illinois
- Darlene Allen, M.S.
- Director
- Child Welfare Services
- Children's Friend and Services
- Providence, Rhode Island
- Michael D. De Bellis, M.D.
- Assistant Professor of Psychiatry
- Developmental Traumatology Laboratory
- University of Pittsburgh Medical Center
- Pittsburgh, Pennsylvania
- Pamela L. Donaldson, A.R.N.P-C., C.A.R.N, Ph.D.
- Post-Doctoral Fellow
- New York State Psychiatric Institute
- Columbia University
- Hackensack, New Jersey
- James Herrera, M.A., L.P.C.C.
- Center on Alcoholism, Substance Abuse and Addictions
- University of New Mexico
- Albuquerque, New Mexico
- Margo H. Juarez, L.A.D.A.C., R.I.M.H.C.
- Albuquerque Metropolitan Central Intake
- Albuquerque, New Mexico
- Lewis Jay Lester, M.S.W., L.C.S.W.
- Briceland, California
- Herschel Swinger, Ph.D.
- Children's Institute International
- Los Angeles, California