# Appendix G—Field Reviewers

- Judith A. Arroyo, Ph.D.
- Coordinator
- Project COMBINE
- University of New Mexico
- Center on Alcoholism, Substance Abuse and Addictions
- Albuquerque, New Mexico

- Eileen Bagus, M.A., M.S.W., L.S.W., Ph.D.
- Clinical Service Provider
- Adult Services
- Talbert House
- Cincinnati, Ohio

- Rodolfo Briseno, L.C.D.C.
- Coordinator for Cultural/Special Populations and Youth Treatment
- Program Services, Program Initiatives
- Texas Commission on Alcohol and Drug Abuse
- Austin, Texas

- Brenda F. Carlin
- President/Founder
- Survivors Unlimited, Inc.
- Sulphur, Lousiana

- Candace R. Charkow
- Treatment Program Manager
- Division of Family Services
- Department of Services for Children, Youth, and Their Families
- Wilmington, Delaware

- Dorynne Czechowicz, M.D.
- Associate Director
- Division of Clinical and Services Research
- Treatment Research Branch
- National Institute on Drug Abuse
- Bethesda, Maryland

- Elaine Engelsted, J.D., C.S.A.C.
- Writer
- Kailua Kona, Hawaii

- Gary L. Fisher, Ph.D.
- Nevada Addiction Technology Transfer Center
- College of Education
- University of Nevada at Reno
- Reno, Nevada

- Cynthia Flackus, M.S.W., L.I.C.S.W.
- Therapist
- CAMP SHARE
- Renewal Center
- Walker, Minnesota

- Linda E. Friedman, Ed.D., L.P.C.C., M.A.
- Clinical Counselor
- Treatment Division
- University of New Mexico
- Center on Alcoholism, Substance Abuse and Addictions
- Albuquerque, New Mexico

- Esther Giller, M.A.
- President and Director
- Sidran Foundation and Press
- Lutherville, Maryland

- Karol A. Kaltenbach, Ph.D.
- Clinical Associate Professor of Pediatrics, Psychiatry and Human Behavior
- Director
- Maternal Addiction: Treatment Education and Research (MATER)
- Department of Pediatrics
- Jefferson Medical College
- Philadelphia, Pennsylvania

- Loretta Kowal, L.I.C.S.W.
- Wabon, Massachusetts

- Martha Kurgans, M.A.
- Assistant Professor
- Department of Psychiatry
- Division of Addictive Medicine
- Virginia Commonwealth University
- Medical College of Virginia Hospital
- Richmond, Virginia

- Kerry Locklear, L.C.S.W., M.S.W.
- Private Practitioner, Child Protective Services Worker
- Family Youth and Children
- Sonoma County Human Services Department
- Santa Rosa, California

- Russell P. MacPherson, Ph.D., C.A.P., C.A.P.P.,
- C.C.P., D.A.C., D.V.C.
- President
- RPM Addiction Prevention Training
- Deland, Florida

- Susan E. Martin, Ph.D.
- Program Manager
- Prevention Research Branch
- National Institute on Alcohol and Alcoholism
- Rockville, Maryland

- Catherine McAlpine, Ph.D., L.C.S.W.-C, M.S.W.
- Clinical Supervisor
- Adult Addiction Services
- Montgomery County Department of Health and Human Services
- Rockville, Maryland

- Martha A. Medrano, M.D., M.P.H.
- Assistant Professor
- Health Science Center at San Antonio Medical School
- Department of Psychiatry
- The University of Texas
- San Antonio, Texas

- Thomas Nicholson, Ph.D, M.P.H., M.A.Ed.
- Professor
- Department of Public Health
- Western Kentucky University
- Bowling Green, Kentucky

- Patricia A. Paluzzi, C.N.M., M.P.H.
- Associate Medical Director
- Clinical Services
- Planned Parenthood of Maryland
- Baltimore, Maryland

- Peter Panzarella, M.A., M.S.
- Director of Substance Abuse Services
- Health Management
- Department of Children and Families
- Hartford, Connecticut

- Scott M. Reiner, M.S., C.A.C., C.C.S.
- Substance Abuse Program Supervisor
- Substance Abuse Services Unit
- Virginia Department of Juvenile Justice
- Richmond, Virginia

- Margaret M. Salinger, M.S.N., R.N., C.A.R.N.
- Audubon, Pennsylvania

- Lois D. Sharp, M.S.
- Doctoral Candidate
- Palo Alto VA Health Care System
- National Center for PSTD and Pacific Graduate School of Psychology
- Palo Alto, California

- Tracy Lynn Simpson, M.S.
- Seattle, Washington
- Christine Smith, M.S.W.
- Senior Analyst
- ABT Associates
- Cambridge, Massachusetts

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Nancy E. Suchman, Ph.D.
- Associate Research Scientist
- Child and Family Research
- Yale University School of Medicine
- New Haven, Connecticut

- Pamela Valentine, Ph.D., M.S.W.
- Assistant Professor
- Department of Government and Public Service-Social Work Program
- School of Social and Behavioral Sciences
- University of Alabama at Birmingham
- Birmingham, Alabama

- Charles L. Whitfield, M.D.
- Atlanta, Georgia

- Katherine Wingfield, M.S.W.
- Program Manager
- Chemical Dependency Initiative
- Child Welfare League of America
- Washington, D.C.