# Appendix F --Resource Panelists

- Cheryl A. Boyce, Ph.D.
- Developmental Psychology
- Society for Research in Child Development
- Rockville, Maryland

- Jutta H. Butler
- Public Health Advisor
- Systems Improvement Branch
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Peter J. Cohen, M.D., J.D.
- Visiting Professor of Law
- Georgetown University
- Washington, D.C.

- Michael D. De Bellis, M.D.
- Assistant Professor of Psychiatry
- Developmental Traumatology Laboratory
- University of Pittsburgh Medical Center
- Pittsburgh, Pennsylvania

- Deborah Duran, Ph.D.
- Research and Policy
- National Coalition of Hispanic Health
- Washington, D.C.

- Laura Feig, M.P.P.
- Social Science Analyst
- Division of Children and Youth Policy
- Office of the Assistant Secretary for Planning and Evaluation
- Department of Health and Human Services
- Washington, D.C.

- Loretta Finnegan, M.D.
- Office of the Director
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Malcolm Gordon, Ph.D.
- Chief
- Child Trauma and Victimization Program
- Developmental Psychology Research Branch
- National Institute of Mental Health
- Rockville, Maryland

- Helen Howerton, M.A.
- Director
- Child and Family Development
- Office of Planning, Research, and Evaluation
- Administration for Children and Families
- Washington, D.C.

- Jenny Collier McColl
- Legislative Counsel
- Legal Action Center
- Washington, D.C.

- Lynn Moore
- Program Specialist
- National Clearinghouse on Child Abuse and Neglect Information
- Fairfax, Virginia

- Hector Sanchez
- Public Health Advisor
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Elizabeth Sloan, L.P.C.
- Director
- Clinical Affairs
- American Academy of Child and Adolescent Psychiatry
- Washington, D.C.

- Richard T. Suchinsky, M.D.
- Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.