# Appendix E --Resources Related to Childhood Trauma Among Adults

The following entries represent a range of resources, consultation, and expertise related to childhood abuse and neglect. Many of these can provide in-service training, targeted consultation for individual clients, or ongoing expertise with regard to screening, assessment, treatment, and referral of adults with histories of childhood trauma.

## Associations and Societies

American Academy of Pediatrics 141 Northwest Point Boulevard P.O. Box 927 Elk Grove Village, IL 60009-0927 Phone: (708) 228-5005 Fax: (708) 228-5097 Web site: http://www.aap.org

American Bar Association Center on Children and the Law 1800 M Street, NW, Suite 200 Washington, DC 20036 Phone: (202) 331-2250 Email: ctrchildlaw@abanet.org Web site: http://www.abanet.org/child /home

American Professional Society on Abuse and Children 332 South Michigan Avenue, Suite 1600 Chicago, IL 60604 Phone: (312) 554-0166 Email: APSACMems@aol.com Web site: http://www.apsac.org

American Psychiatric Association 1400 K Street, NW Washington, DC 20005 Phone: (202) 682-6083 Fax: (202) 682-6353 Email: apa@psych.org Web site: http://www.psych.org

American Psychological Association 750 First Street, NE Washington, DC 20002-4242 Phone: (202) 336-5500 Fax: (202) 336-6080 Email: rdf.apa@email.apa.org Web site: http://www.apa.org

American Public Human Services Association 810 First Street, NE, Suite 500 Washington, DC 20002 Phone: (202) 682-0100 Web site: http://www.aphsa.org

American Society of Addiction Medicine Arcade, Suite 101 4601 North Park Avenue Chevy Chase, MD 20815 Phone: (301) 656-3920 Fax: (301) 656-3815 Web site: http://www.asam.org

Child Welfare League of America 440 First Street, NW, 3rd Floor Washington, DC 20001 Phone: (202) 638-2952 Fax: (202) 638-4004 Web site: http://www.cwla.org

The International Society for the Prevention of Child Abuse and Neglect 401 North Michigan Avenue, Suite 2200 Chicago, IL 60611 Phone: (312) 644-6610, ext. 3273 Email: kim_svevo@sba.com Web site: http://child.cornell.edu/

International Society for Traumatic Stress Studies 60 Revere Drive, Suite 500 Northbrook, IL 60062 Phone: (847) 480-9028 Email: istss@istss.com Web site: http://www.istss.com

International Society for the Study of Dissociation 60 Revere Drive, Suite 500 Northbrook, IL 60062 Phone: (847) 480-0899 Fax: (847) 480-9282 Web site: http://www.issd.org

National Mental Health Association 1201 Prince Street Alexandria, VA 22314-2971 Phone: (703) 684-7722 Web site: http://www.nmha.org

## Organizations and Clearinghouses

Local crisis lines often have referrals to local organizations.

Anxiety Disorders Association of America 6000 Executive Boulevard, Department A Rockville, MD 20852 Phone: (301) 231-9350 Email: anxdis@aol.com Web site: http://www.adaa.org

Center for the Prevention of Sexual and Domestic Violence 936 North 34th Street, Suite 200 Seattle, WA 98103 Phone: (206) 634-1903 Email: cpsdv@cpsdv.seanet.com Web site: http://www.cpsdv.org

Domestic Violence Training Project 900 State Street New Haven, CT 06511 Phone: (203) 865-3699

Family Violence and Sexual Assault Institute 1121 ESE Loop 323, Suite 130 Tyler, TX 75701 Phone: (903) 534-5100 Email: fvsai@iamerica.net Web site: http://www.gatekeep.net/fvsai/index.html

National Abandoned Infants Assistance Resource Center 1950 Addison Street, Suite 104 Berkeley, CA 94704-1182 Phone: (510) 643-7020 Fax: (510) 643-7019

National Alliance for the Mentally Ill 200 North Glebe Road, Suite 1015 Arlington, VA 22203-3754 Phone: (800) 950-6264 Web site: http://www.nami.org

National Center on Child Abuse and Neglect P.O. Box 1182 Washington, DC 20013 Phone: (703) 385-7565 Email: nccanch@calib.com Web site: http://www.calib.com/nccanch

National Center for PTSD VA Medical Center (116D) White River Junction, VT 05009 Phone: (802) 296-5132 Email: ptsd@dartmouth.edu Web site: http://www.dartmouth.edu/dms/ptsd

National Clearinghouse on Child Abuse and Neglect Information P.O. Box 1182 Washington, DC 20013-1182 Phone: (800) FYI-3366 Email: nccanch@calib.com Web site: http://www.calib.com/nccanch

National Coalition Against Domestic Violence P.O. Box 18749 Denver, CO 80218 Phone: (303) 839-1852 Web site: http//www.webmerchants.com/ncadv

National Committee to Prevent Child Abuse P.O. Box 2866 Chicago, IL 60690-9950 [or] 200 South Michigan Avenue, 17th Floor Chicago, IL 60604-2404 Phone: (800) CHILDREN, or (312) 663-3520 Fax: (312) 939-8962 Email: ncpca@childabuse.org Web site: http//www.childabuse.org

National Mental Health Consumers' Self-Help Clearinghouse 1211 Chestnut Street Philadelphia, PA 19107 Phone: (800) 553-4539 Email mhselfhelp@libertynet.org Web site: http://www.mhselfhelp.org

National Children's Advocacy Center 200 Westside Square, Suite 700 Huntsville, AL 35801 Phone: (256) 533-0531 Fax: (256) 534-6883 Email: webmaster@ncac-hsv.org Web site: http://ncac-hsv.org

National Victim Center Infolink Phone: (800) FYI-CALL Phone: (703) 276-2880 Web site: http://www.nvc.org

One Voice/The National Coalition for Abuse Awareness P.O. Box 27958 Washington, DC 20038-7958 Phone: (202) 462-4688 or (202) 667-1160 (resource line) Fax (202) 462-4689 Email: Ovicedc@aol.com or ACAADC@aol.com

The Sidran Foundation 2328 West Joppa Road, Suite 15 Lutherville, MD 21093 Phone: (410) 825-8888 Email: sidran@sidran.org Web site: http://www.sidran.org

Zero to Three National Center for Infants, Toddlers, and Families 734 Fifteenth Street, NW Suite 1000 Washington, D.C. 20005-1013 Phone: (202) 638-1144 FAX: (202) 638-0851 Web site: http://www.zerotothree.org

## Publications

Moving Forward (A semi-annual newsletter for survivors of childhood sexual abuse) P.O. Box 4426 Arlington, VA 22204 Phone: (703) 271-4024

Once Upon a Time: Therapeutic Stories To Heal Abused Children Nancy Davis, Ph.D. 6178 Oxon Hill Rd. Suite 306 Oxon Hill, MD 20745 Phone: (301) 567-9297